# References

Abboud TK, Zhu J, Gangolly J, Longhitano M, Swart F, Makar A, Chu G, Cool M, Mantilla M, Kurtz N. Transnasal butorphanol: a new method for pain relief in post-cesarean section pain. Acta Anaesthesiol Scand. 1991;35(1):14-8. [pmid: 2006593].
Abel EL. Opiates and sex. J Psychoactive Drugs. 1984;16(3):205-16. [pmid: 6092595].
Abram SE (editor). Cancer Pain. Boston: Kluwer Academic Publishers. 1989.
Acute Pain Management Guideline Panel. Acute pain management. AHCPR Pub. No. 92-0032. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, US Department of Health and Human Services. 1992.
Acute Pain Management Guideline Panel. Acute Pain Management: Operative or Medical Procedures and Trauma. in press.
Ad Hoc Committee on Cancer Pain of the American Society of Clinical Oncology. Cancer Pain Assessment and Treatment Curriculum Guidelines. J Clin Oncol. 1992;10(12):1976-82. [pmid: 1453212].
Adams F, Fernandez F, Andersson BS. Emergency pharmacotherapy of delirium in the critically ill cancer patient. Psychosomatics. 1986 Jan;27(1 Suppl):33-8. [pmid: 3952253].
Adams F, Quesada JR, Gutterman JU. Neuropsychiatric manifestations of human leukocyte interferon therapy in patients with cancer. JAMA. 1984;252(7):938-41. [pmid: 6748198].
Adams J. A methodological study of pain assessment in Anglo and Hispanic children with cancer. In: Tyler DC, Krane EJ, editors. Pediatric pain. Vol. 15. Advances in pain research and therapy. New York: Raven Press, Ltd. 1990:p. 43-51.
Adams JE, Lippert R, Hosobuchi Y. Commissural myelotomy. In: Schmidek HH, Sweet WH, editors. Operative neurosurgical techniques: indications, methods, and results. 2nd ed. Vol. 2. Philadelphia: WB Saunders Co. 1988:p. 1185-9.
Ahles TA, Blanchard EB, Ruckdeschel JC. The multidimensional nature of cancer-related pain. Pain. 1983;17(3):277-88. [pmid: 6657288].
Akerman B, Arwestrom E, Post C. Local anesthetics potentiate spinal morphine antinociception. Anesth Analg. 1988;67:943-8. [pmid: 3421498].
Amano K, Kawamura H, Tanikawa T, Kawabatake H, Iseki H, Iwata Y, Taira T. Bilateral versus unilateral percutaneous high cervical cordotomy as a surgical method of pain relief. Acta Neurochir (Wien). 1991;52(suppl.):143-5.
American Academy of Pediatrics. Guidelines for the elective use of conscious sedation, deep sedation, and general anesthesia in pediatric patients. Pediatrics. 1985;76(2):317-21. [pmid: 4022709].
American Academy of Pediatrics Committee on Drugs. Guidelines for monitoring and management of pediatric patients during and after sedation for diagnostic and therapeutic procedures. Pediatrics. 1992;89(6):1110-5. [pmid: 1594358].
American Cancer Society. Cancer and the poor: a report to the nation. American Cancer Society. 1989.
American Cancer Society. Cancer facts and figures—. Atlanta: American Cancer Society Inc. 1994. 1994.
American Cancer Society. Questions and answers about pain control. American Cancer Society and the National Cancer Institute. 1992.
American Nurses Association. Position statement on the role of the registered nurse (RN) in the management of patients receiving IV conscious sedation for short-term therapeutic, diagnostic, or surgical procedures. Nov.1991.
American Pain Society. Principles of analgesic use in the treatment of acute pain and chronic cancer pain: a concise guide to medical practice. Skokie, IL: American Pain Society. 1986 [updated 1989, 1992].
American Pain Society. Principles of analgesic use in the treatment of acute pain and chronic cancer pain: a concise guide to medical practice. Skokie, IL: American Pain Society. 1992.
American Pain Society. Committee of Quality Assurance Standards. American Pain Society quality assurance standards for relief of acute pain and cancer pain. In: Bond MR, Charlton JE, Woolf CJ, editors. Proceedings of the Sixth World Congress on Pain. New York: Elsevier Science Publications. 1991:p. 185-90.
American Pain Society, Committee on Quality Assurance Standards. Standards for monitoring quality of analgesic treatment of acute pain and cancer pain. Oncol Nurs Forum. 1990;17:952-4. [pmid: 2263523].
Angarola R. National and international regulation of opioid drugs: purpose, structures, benefits and risks. J Pain Symptom Manage. 1990;5(2 suppl.):S6-11. [pmid: 2324565].
Angarola RT, Wray SD. Legal impediments to cancer pain treatment. In: Hill CS, Fields WS, editors. Drug treatment of cancer pain in a drug-oriented society. Vol. 11. Advances in pain research and therapy. New York: Raven Press, Ltd. 1989:p. 213-31.
Arbit E, Galicich JH, Burt M, Mallya K. Modified open thoracic rhizotomy for treatment of intractable chest wall pain of malignant etiology. Ann Thorac Surg. 1989;48(6):820-3. [pmid: 2480758].
Arcangeli G, Micheli A, Arcangeli G, Giannarelli D, La Pasta O, Tollis A, Vitullo A, Ghera S, Benassi M. The responsiveness of bone metastases to radiotherapy: the effect of site, histology and radiation dose on pain relief. Radiother Oncol. 1989;14(2):95-101. [pmid: 2469105].
Ascari E, Attardo-Parrinello G, Merlini G. Treatment of painful bone lesions and hypercalcemia. Eur J Haematol. 1989;43 (suppl 51):135-9.
Attardo-Parrinello G, Merlini G, Pavesi F, Crema F, Fiorentini ML, Ascari E, van Holten-Verzantvoort AT, Zwinderman AH, Aaronson NK, Hermans J, van Emmerik B, van Dam FS, van den Bos B, Bijvoet OL, Cleton FJ. Effects of a new aminodiphosphonate (aminohydroxybutylidene diphosphonate) in patients with osteolytic lesions from metastases and myelomatosis. Comparison with dichloromethylene diphosphonate. Arch Intern Med. 1987;147(9):1629-33. [pmid: 2957971].
Avellanosa AM, West CR. Experience with transcutaneous electrical nerve stimulation for relief of intractable pain in cancer patients. J Med. 1982;13(3):203-13. [pmid: 6983553].
Bach FW, Jensen TS, Kastrup J, Stigsby B., Dejgard A. The effect of intravenous lidocaine on nociceptive processing in diabetic neuropathy. Pain. 1990;40(1):29-34. [pmid: 2339012].
Baker DG. The radiobiological basis for tissue reactions in the oral cavity following therapeutic x-irradiation. A review. Arch Otolaryngol. 1982;108(1):21-4.
Barbour LA, McGuire DB, Kirchhoff KT. Nonanalgesic methods of pain control used by cancer outpatients. Oncol Nurs Forum. 1986;13(6):56-60. [pmid: 3642565].
Bates T. A review of local radiotherapy in the treatment of bone metastases and cord compression. Int J Radiat Oncol Biol Phys. 1992;23(1):217-21. [pmid: 1374063].
Bates T, Yarnold JR, Blitzer P, Nelson OS, Rubin P, Maher J. Bone metastasis consensus statement. Int J Radiat Oncol Biol Phys. 1992;23(6):215-6. [pmid: 1374062].
Bauchner H, Waring C, Vinci R. Parental presence during procedures in an emergency room: results from 50 observations. Pediatrics. 1991;87(4):544-8. [pmid: 2011433].
Bauer W. Electrical treatment of severe head and neck cancer pain. Arch Otolaryngol. 1983;109(6):382-3. [pmid: 6601946].
Baumann TJ, Batenhorst RL, Graves DA, Foster TS, Bennett RL. Patient-controlled analgesia in the terminally ill cancer patient. Drug Intell Clin Pharm. 1986;20(4):297-301. [pmid: 2421993].
Beaver WT, Feise G. Comparison of the analgesic effects of morphine, hydroxyzine, and their combination in patients with postoperative pain. In: Bonica JJ, Albe-Fessard DG, editors. Proceedings of the First World Congress on Pain. Florence, Italy. Vol. 1. Advances in pain research and therapy. New York: Raven Press, Ltd. 1976:p. 553-7.
Beaver WT, Wallenstein SL, Houde RW, Rogers A. A comparison of the analgesic effects of methotrimeprazine and morphine in patients with cancer. Clin Pharmacol Ther. 1966;7(4):436-46. [pmid: 5328470].
Beck SL. The therapeutic use of music for cancer-related pain. Oncol Nurs Forum. 1991;18(8):1327-37. [pmid: 1762973].
Behar M, Magora F, Olshwang D, Davidson JT. Epidural morphine in treatment of pain. Lancet. 1979;1(8115):527-9. [pmid: 85109].
Bellville JW, Dorey F, Capparell D, Knox V, Bauer RO. Analgesic effects of hydroxyzine compared to morphine in man. J Clin Pharmacol. 1979;19(5-6):290-6. [pmid: 381334].
Berde CB. Convulsions associated with pediatric regional anesthesia. Anesth Analg. 1992;75(2):164-6. [pmid: 1632529].
Berde CB. The treatment of pain in children. In: Bond MR, Charlton JE, Woolf CJ, editors. Proceedings of the Seventh World Congress on Pain. New York: Elsevier Science Publishers. 1991:p.435-40.
Berde CB, Fischel N, Filardi JP, Coe CS, Grier HE, Bernstein SC. Caudal epidural morphine analgesia for an infant with advanced neuroblastoma. Pain. 1989;36(2). 219. 23. [pmid: 2919102].
Berde CB, Lehn BM, Yee JD, Sethna NF, Russo D. Patient-controlled analgesia in children and adolescents: a randomized, prospective comparison with intramuscular administration of morphine for postoperative analgesia. J Pediatr. 1991;118(3):460-6. [pmid: 1999793].
Beyer JE, McGrath PJ, Berde CB. Discordance between self-report and behavioral pain measures in children aged 3-7 years after surgery. J Pain Symptom Manage. 1990;5(6):350-6. [pmid: 2269802].
Beyer JE, Villarruel AM, Denyes M. The Oucher: The new user's manual and technical report. 1st ed. February 1993.
Beyer JE, Wells N. Assessment of cancer pain in children. In: Patt RB, editor. Cancer pain. Philadelphia: JB Lippincott. 1993:p. 57-84.
Blendon RJ, Aiken LH, Freeman HE, Corey CR. Access to medical care for black and white Americans. A matter of continuing concern. JAMA. 1989;261(2):278-81. [pmid: 2909026].
Blitzer PH. Reanalysis of the RTOG study of the palliation of symptomatic osseous metastasis. Cancer. 1985;55(7):1468-72. [pmid: 2579716].
Boland M, Mahan-Rudolph P, Evans P. Special issues in the care of the child with HIV infection/AIDS. In: Pediatric hospice care: what helps. Los Angeles: Los Angeles Children's Hospital. 1989.:p. 116-74.
Bolund C. Suicide and cancer. J Psychosoc Oncol. 1985;3:II. Medical and care factors in suicide by cancer patients in Sweden. 1973-1976. 17. 30.
Bonica JJ. Cancer pain. In: Bonica JJ, editor. The management of pain. 2nd ed. Vol. 1. Philadelphia: Lea and Febiger. 1990:p.400-60.
Bonica JJ. Treatment of cancer pain: current status and future need. In: Fields HL, Dubner R, Cervero R, editors. Proceedings of the Fourth World Congress on Pain; Seattle, Washington, Aug 31-Sept 5, 1984. Vol. 9, Advances in pain research and therapy. New York: Raven Press, Ltd. 1985:p. 589-616.
Bonica JJ, Buckley FP, Moricca G, Murphy TM. Neurolytic blockade and hypophysectomy. In: Bonica JJ, editor. The management of pain. 2nd ed. Vol. 1. Philadelphia: Lea and Febiger. 1990:p. 1980-2039.
Botney M, Fields HL. Amitriptyline potentiates morphine analgesia by a direct action on the central nervous system. Ann Neurol. 1983;13(2):160-4. [pmid: 6219612].
Brand F, Smith R, Grand T. Effect of economic barriers to medical care on patients' noncompliance. Public Health Rep. 1977;92:72-8. [pmid: 189344]. [pmcid: 1431971].
Breitbart W. Cancer pain and suicide. In: Foley KM, Bonica JJ, Ventafridda V, editors. Proceedings of the Second International Congress on Cancer Pain, Rye, New York, July 14-17, 1988. Vol. 16. Advances in pain research and therapy. New York: Raven Press, Ltd. 1990a:p. 399-412.
Breitbart W. Endocrine-related psychiatric disorders. In: Holland JC, Rowland JH, editors. The handbook of psychooncology: psychological care of the patient with cancer. New York: Oxford University Press. 1989:p. 356-68.
Breitbart W. Psychiatric aspects of pain and HIV disease. Focus. A guide to AIDS research and counseling. 1990b;5(9):1-3.
Breitbart W. Suicide risk and pain in cancer and AIDS patients. In: Chapman CR, Foley KM, editors. Current and emerging issues in cancer pain: research and practice. New York: Raven Press, Ltd. 1993:p. 49-65.
Breitbart W, Holland JC. Psychiatric complications of cancer. In: Brain MC, Carbone PP, editors. Current therapy in hematology-oncology—. 1988;3. Philadelphia: BC Decker Inc.:p. 268-74.
Breitbart W, Passik S, Bronaugh T, Zale C, Bluestine S, Gomez M, Galer B, Portenoy R. Pain in the ambulatory AIDS patient: prevalence and psychosocial correlates. Proceedings of the 38th Annual Meeting, Academy of Psychosomatic Medicine. 1991;October 17-20. 1991. p. 60.
Brennan SC, Redd WH, Jacobsen PB, Schorr O, Heelan RT, Sze GK, Krol G, Peters BE, Morrissey JK. Anxiety and panic during magnetic resonance scans. Lancet. 1988; 2(8609). [pmid: 2900435].
Bromage PR, Camporesi EM, Durant PAC, Nielsen CH. Rostral spread of epidural morphine. Anesthesiology. 1982;56:431-6. [pmid: 7081727].
Brose WG, Cousins MJ. Subcutaneous lidocaine for treatment of neuropathic cancer pain. Pain. 1991;45(2):145-8. [pmid: 1876421].
Brown DL, Bulley CK, Quiel EL. Neurolytic celiac plexus block for pancreatic cancer pain. Anesth Analg. 1987;66(9):869-73. [pmid: 3619093].
Bruera E, Brenneis C, MacDonald RN. Continuous Sc infusion of narcotics for the treatment of cancer pain: an update. Cancer Treat Rep. 1987;71(10):953-8. [pmid: 2443242].
Bruera E, Brenneis C, Paterson AH. Use of methylphenidate as an adjuvant to narcotic analgesics in patients with advanced cancer. J Pain Symptom Manage. 1989;4(1):3-6. [pmid: 2703735].
Bruera E, Chadwick S, Brenneis C, Hanson J, MacDonald RN. Methylphenidate associated with narcotics for the treatment of cancer pain. Cancer Treat Rep. 1987;71(1):67-70. [pmid: 3791269].
Bruera E, Macmillan K, Hanson J, MacDonald RN. The cognitive effects of the administration of narcotic analgesics in patients with cancer pain. Pain. 1989;39(1):13-6. [pmid: 2812850].
Bruera E, Miller MJ, Macmillan K, Kuehn N. Neuropsychological effects of methylphenidate in patients receiving a continuous infusion of narcotics for cancer pain. Pain. 1992;48(2):163-6. [pmid: 1589233].
Bruera E, Roca E, Cedaro L, Carraro S, Chacon R. Action of oral methylprednisolone in terminal cancer patients: a prospective randomized double-blind study. Cancer Treat Rep. 1985;69(7-8):751-54. [pmid: 2410117].
Bruera E, Schoeller T, Montejo G. Organic hallucinosis in patients receiving high doses of opiates for cancer pain. Pain. 1992;48(3):397-9. [pmid: 1375722].
Bullingham RES, McQuay HJ, Moore RA. Extradural and intrathecal narcotics. In: Atkinson RS, Hewer CL, editors. Vol. 14. Recent advances in anesthesia and analgesia. New York: Churchill Livingstone. 1982:p. 141-56.
Burkberg J, Penman D, Holland JC. Depression in hospitalized cancer patients. Psychosom Med. 1984;46(3):199-212. [pmid: 6739680].
Byrne TN. Spinal cord compression from epidural metastases. N Engl J Med. 1992;327(9):614-9. [pmid: 1296600].
Cain JM, Hammes B. Ethics and pain management: respecting patient wishes. J Pain Symptom Manage in press.
Campos RG. Soothing pain-elicited distress in infants with swaddling and pacifiers. Child Dev. 1989;60(4):781-92. [pmid: 2758876].
Cassel EJ. The nature of suffering and the goals of medicine. N Engl J Med. 1982;306(11):639-45. [pmid: 7057823].
Chapman CR, Hill HF. Prolonged morphine self-administration and addiction liability. Evaluation of two theories in a bone marrow transplant unit. Cancer. 1989;63(8):1636-44. [pmid: 2466551].
Charlton JE. Current views on the use of nerve blocking in the relief of chronic pain. In: Swerdlow M, editor. The therapy of pain. 2nd edition. Lancaster: MTP Press, Ltd. 1986:p. 133-64.
Chauvin M, Samii K, Schermann JM, Sandouk P, Bourdon R, Viars P. Plasma pharmacokinetics of morphine after i.m., extradural and intrathecal administration. Br J Anaesth. 1982;54(8):843-7. [pmid: 6896649].
Choi CR, Ha YS, Ahn MS, Lee JS, Song JU. Intraventricular or epidural injection of morphine for severe pain. Neurochirurgia (Stuttg). 1989;32(6):180-3. [pmid: 2594133].
Citron ML, Johnston-Early A, Boyer M, Krasnow SH, Hood M, Cohen MH. Patient-controlled analgesia for severe cancer pain. Arch Intern Med. 1986;146(4):734-6. [pmid: 2421659].
Cleeland CS. Barriers to the management of cancer pain. Oncology. 1987;1(2 suppl.):19-26. [pmid: 2484445].
Cleeland CS. Management of cancer pain. Clin Cancer Briefs. 1985;7(3):3-12.
Cleeland CS. Measurement of pain by subjective report. In: Chapman CR, Loeser JD, editors. Issues in pain measurement. Vol. 12. Advances in pain research and therapy. New York: Raven Press, Ltd. 1989a:p. 391-404.
Cleeland CS. Pain control. In: Hill CS Jr, Fields WS, editors. Drug treatment of cancer pain in a drug-oriented society. Vol. 11. Advances in pain research and therapy. New York: Raven Press, Ltd. 1989b. p. 81. 9.
Cleeland CS. The impact of pain on the patient with cancer. Cancer. 1984;54:2635-41. [pmid: 6498754].
Cleeland CS, Cleeland LM, Dar R, Rinehardt LC. Factors influencing physician management of cancer pain. Cancer. 1986;58(3):796-800. [pmid: 2873882].
Cleeland CS, Gonin R, Hatfield AK, Edmonson JH, Blum RH, Stewart JA, Pandya KJ. Pain and pain treatment in outpatients with metastatic cancer: the Eastern Cooperative Oncology Group's Outpatient Pain Study. N Engl J Med. in press.
Cleeland CS, Syrjala KL. How to assess cancer pain. In: Turk D, Melzack R, editors. Pain assessment. New York: Guilford Press. 1992:p. 360-87.
Cohn ML, Machado AF, Bier R, Cohn M. Piroxicam and doxepin—an alternative to narcotic analgesics in managing advanced cancer pain. West J Med. 1988; 148(3):303-6. [pmid: 3363962].
Collins C, Koren G, Crean P, Klein J, Roy WL, MacLeod SM. Fentanyl pharmacokinetics and hemodynamic effects in preterm infants during ligation of patent ductus arteriosus. Anesth Analg. 1985;64(11):1078-80. [pmid: 3840338].
Controlled Substances Act, 21 U. S.C., sec 802. (West). 1981).
Cook PR, Campbell FN, Puddy BR. Pituitary alcohol injection for cancer pain. Anesthesia. 1984;39(6):540-5.
Cornblath DR, McArthur JC. Predominantly sensory neuropathy in patients with AIDS and AIDS-related complex. Neurology. 1988;38(5):794-6. [pmid: 2834669].
Cousins MJ. The spinal route of analgesia. Acta Anaesthesiol Belg. 1988;39(3 suppl. 2):71-82. [pmid: 2902731].
Cousins MJ, Bridenbaugh PO, editors. Neural blockade in clinical anesthesia and management of pain. 2nd ed. Philadelphia: JB Lippincott Co. 1987.
Cousins MJ, Mather LE. Intrathecal and epidural administration of opioids. Anesthesiology. 1984;61:276-310. [pmid: 6206753].
Coyle N, Adelhardt J, Foley KM, Portenoy RK. Character of terminal illness in the advanced cancer patient: pain and other symptoms during the last four weeks of life. J Pain Symptom Manage. 1990;5(2):83-93. [pmid: 2348092].
Craig KD. The facial expression of pain: better than a thousand words?. APS Journal. 1992;1(3):153-62.
Cronin C, Edmiston K, Griffin T. Hematologic safety of choline magnesium trisalicylate: a non-opioid analgesic. J Pain Symptom Manage. 1991;6(3).
Crook J, Rideout E, Browne G. The prevalence of pain complaints in a general population. Pain. 1984;18(3):299-314. [pmid: 6728496].
Dahl JL, Joranson DE, Engber D, Dosch J. The cancer pain problem: Wisconsin's response. A report on the Wisconsin Cancer Pain Initiative. J Pain Symptom Manage. 1988;3(1):S1-20. [pmid: 3418171].
Danesh BJ, Saniabadi AR, Russell RI, Lowe GD. Therapeutic potential of choline magnesium trisalicylate as an alternative to aspirin for patients with bleeding tendencies. Scott Med J. 1987;32(6):167-8. [pmid: 3329766].
Dar R, Beach CM, Barden PL, Cleeland CS. Cancer pain in the marital system: a study of patients and their spouses. J Pain Symptom Manage. 1992;7(2):87-93. [pmid: 1573290].
Daut RL, Cleeland CS. The prevalence and severity of pain in cancer. Cancer. 1982;50(9):1913-8. [pmid: 7116316].
Davis GC, Cortex C, Rubin BR. Pain management in the older adult with rheumatoid arthritis or osteoarthritis. Arthritis Care Res. 1990;3(3):127-31. [pmid: 2285751].
Davis LE, Drachman DB. Myeloma neuropathy. Successful treatment of two patients and review of cases. Arch Neurol. 1972;27(6):507-11. [pmid: 4343458].
Day RO, Furst DE, Graham GG, Champion GD. The clinical pharmacology of aspirin and the salicylates. In: Paulus HE, Furst DE, Dromgoole SH, editors. Anti-inflammatory agents, non-steroidal. 1987;Vol. 16. Drugs for rheumatic disease. New York: Churchill Livingstone:p. 227-64.
DeAngelis LM, Delattre JY, Posner JB. Radiation-induced dementia in patients cured of brain metastases. Neurology. 1989;39(6):789-96. [pmid: 2725874].
Dejgard A, Petersen P, Kastrup J. Mexiletine for treatment of chronic painful diabetic neuropathy. Lancet. 1988;1:9-11. [pmid: 2891940].
Delmas PD, Charhon S, Chapuy MC, Vignon E, Briancon D, Edouard C, Meunier PJ. Long-term effects of dichloromethylene diphosphonate (Cl2MDP) on skeletal lesions in multiple myeloma. Metab Bone Dis Relat Res. 1982;4(3):163-8. [pmid: 6218370].
Depression Guideline Panel. Depression in Primary Care: Vol. 1. Detection and Diagnosis. Clinical Practice Guideline. Number 5. Rockville, MD: US Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research. AHCPR Pub. No. 93-0550. April:1993a.
Depression Guideline Panel. Depression in Primary Care. Treatment of Major Depression. Clinical Practice Guideline. Number 5. April. 1993b;Vol. 2.
Derogatis LR, Morrow GR, Fetting J, Penman D, Piasetsky S, Schmale AM, Henrichs M, Carnicke CL Jr. The prevalence of psychiatric disorders among cancer patients. JAMA. 1983;249(6):751-7. [pmid: 6823028].
Donovan MI, Dillon P. Incidence and characteristics of pain in a sample of hospitalized cancer patients. Cancer Nurs. 1987;10(2):85-92. [pmid: 3646918].
Dray A. Epidural opiates and urinary retention: new models provide new insights. Anesthesiology. 1988;68(3):323-4. [pmid: 2894185].
Dreizen S. Oral complications of cancer therapies. Description and incidence of oral complications. NCI Monogr. 1990;9:11-5. [pmid: 2188148].
Dunphy JE. Annual discourse—. New Engl J Med. 1976;295(6);on caring for the patient with cancer:313-19. [pmid: 934211].
Du Pen SL, Peterson DG, Williams A, Bogosian AJ. Infection during chronic epidural catheterization: diagnosis and treatment. Anesthesiology. 1990;73:905-9. [pmid: 2240680].
Du Pen SL, Ramsey D, Chin S. Chronic epidural morphine and preservative-induced injury. Anesthesiology. 1987;67(6):987-8. [pmid: 3688542].
Du Pen SL, Williams AR. Management of patients receiving combined epidural morphine and bupivacaine for the treatment of cancer pain. J Pain Symptom Manage. 1992;7(2):125-7. [pmid: 1573286].
Egbert AM, Parks LH, Short LM, Burnett ML. Randomized trial of postoperative patient-controlled analgesia vs intramuscular narcotics in frail elderly men. Arch Intern Med. 1990;150(9):1897-903. [pmid: 1975490].
Eisenberg E, Carr D, Chalmers T. Neurolytic celiac plexus block for treatment of cancer pain: a meta-analysis. Submitted for publication.
Eland JM. The effectiveness of transcutaneous electrical nerve stimulation (TENS) with children experiencing cancer pain. In:Funk SG, Tornquist EM, Champagne MT, Copp LA, Wiese RA, editors. Key aspects of comfort: management of pain, fatigue, and nausea. New York: Springer Publishing Co. 1989:p. 87-100.
Ellerton ML, Caty S, Ritchie JA. Helping young children master intrusive procedures through play. Child Health Care. 1985 Spr;13(4):167-73.
Elliott K, Foley KM. Neurologic pain syndromes in patients with cancer. Neurol Clin. 1989;7(2):333-60. [pmid: 2657380].
Ellison NM. Opioid analgesics: toxicities and their treatments. In: Patt RB, editor. Cancer pain. Philadelphia: JB Lippincott Co. 1993:p. 185-94.
Elomaa I, Blomqvist C, Grohn P, Porkka L, Kairento AL, Selander K, Lamberg-Allardt C, Holmstrom T. Long-term controlled trial with diphosphonate in patients with osteolytic bone metastases. Lancet. 1983;1(8317):146-9. [pmid: 6130197].
Endicott J. Measurement of depression in patients with cancer. Cancer. 1984;53(10 suppl:2243-9. [pmid: 6704912].
Epstein JB. Infection prevention in bone marrow transplantation and radiation patients. NCI Monogr. 1990;9:73-85. [pmid: 2111470].
Espinoza LR, Aguilar JL, Berman A, Gutierrez F, Vascy FB, Germain BF. Rheumatic manifestations associated with human immunodeficiency virus infection. Arthritis Rheum. 1989;32(12):1615-22. [pmid: 2688661].
Estes D, Kaplan K. Lack of platelet effect with the aspirin analog, salsalate. Arthritis Rheum. 1980;23(11):1303-7. [pmid: 7447965].
Evans PJ, Lloyd JW, Jack TM. Cryoanalgesia for intractable perineal pain. J R Soc Med. 1981;74(11):804-9. [pmid: 7299782].
Facing forward: A guide for cancer survivors. US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute, July. 1990;NIH Pub. No. 90-2424.
Fainsinger R, Bruera E. Treatment of delirium in a terminally ill patient. J Pain Symptom Manage. 1992;7(1):54-6. [pmid: 1538182].
Fairchild VM, Salerno LM, Wedding SL, Weinberg E. Physical therapy. In: Raj PP, editor. Practical management of pain: with special emphasis on physiology of pain syndromes and techniques of management. Chicago: Yearbook Medical Publishers. 1986:p. 839-52.
Fawzy FI, Cousins N, Fawzy NW, Kemeny ME, Elashoff R, Morton D. A structured psychiatric intervention for cancer patients. I. Changes over time in methods of coping and affective disturbance. Arch Gen Psychiatry. 1990;47(8):720-5. [pmid: 2378543].
Ferrante FM, Ostheimer GW, Covino BG, editors. Patient-controlled analgesia. 1990.
Ferrell BA. Assessment and management of pain in nursing homes. Ann Intern Med, (in press for Annals of Internal Med. Ferrell BA. Pain management in elderly people. J Am Geriatr Soc. 1991. 1994);39(1):64-73. [pmid: 1670940].
Ferrell BA, Ferrell BR, Osterweil D. Pain in the nursing home. J Am Geriatr Soc. 1990;38(4):409-14. [pmid: 2109765].
Ferrell BR, Griffith H. Cost issues related to pain management. J Pain Symptom Manage in press.
Ferrell BR, Cohen MZ, Rhiner M, Rozek A. Pain as a metaphor for illness. Part II: Family caregivers' management of pain. Oncol Nurs Forum. 1991;18(8):1315-21. [pmid: 1762972].
Ferrell BR, Cronin Nash C, Warfield C. The role of patient-controlled analgesia in the management of cancer pain. J Pain Symptom Manage. 1992;7(3):149-54. [pmid: 16967582].
Ferrell BR, Rhiner M, Cohen MZ, Grant M. Pain as a metaphor for illness. Part I: Impact of cancer pain on family caregivers. Oncol Nurs Forum. 1991;18(8):1303-9. [pmid: 1762971].
Ferrell BR, Rhiner M, Ferrell BA. Development and implementation of a pain education program. Cancer. 1993;72(11 suppl.):3426-32. [pmid: 8242574].
Ferris FD, Kerr IG, Sone M, Marcuzzi M. Transdermal scopolamine use in the control of narcotic-induced nausea. J Pain Symptom Manage. 1991;6(6):389-93. [pmid: 1880439].
Fields HL, Basbaum AI. Brainstem control of spinal pain-transmission neurons. Annu Rev Physiol. 1978;40:217-48. [pmid: 205165].
Fine PG. Nerve blocks, herpes zoster, and postherpetic neuralgia. In: Watson CPN, editor. Pain research and clinical management. Vol. 8. Herpes zoster and postherpetic neuralgia. New York: Elsevier Science Publishers. 1993:p. 173-83.
Fish DN. Treatment of delirium in the critically ill patient. Clin Pharm. 1991;10(6):456-66. [pmid: 1676622].
Fishman B, Pasternak S, Wallenstein SL, Houde RW, Holland JC, Foley KM. Memorial Pain Assessment Card: a valid instrument for the evaluation of cancer pain. Cancer. 1987;60(5):1151-8. [pmid: 3300951].
Fleisch H, Russel RGG, Francis MD. Diphosphonates inhibit hydroxyapatite dissolution in vitro and bone resorption in tissue culture in vivo. Science. 1969;165:1262-4. [pmid: 5803538].
Fleishman SB, Lesko LM. Delirium and dementia. In: Holland JC, Rowland JH, editors. The handbook of psychooncology: psychological care of the patient with cancer. New York: Oxford University Press. 1989:p. 342-55.
Foley KM. Brachial plexopathy in patients with breast cancer. In: Harris JR, Hellman S, Henderson IC, Kinne DW, editors. Breast diseases. Philadelphia: JB Lippincott Co. 1987:p. 532-7.
Foley KM. Pain syndromes in patients with cancer. In: Bonica JJ, Ventafridda V, editors. International Symposium on Pain of Advanced Cancer; 1978; Venice. Vol. 2. Advances in pain research and therapy. New York: Raven Press, Ltd. 1979:p. 59-75.
Foley KM. The treatment of cancer pain. N Engl J Med. 1985a;313(2):84-95. [pmid: 2582259].
Foley KM. Overview of cancer pain and brachial and lumbosacral plexopathy. In: Management of cancer pain: syllabus of the postgraduate course, Memorial Sloan-Kettering Cancer Center, 1985 Nov 14-16. New York: Memorial Sloan-Kettering Cancer Center. 1985b:p. 25-50.
Foley KM. Changing concepts of tolerance to opioids. In: Chapman CR, Foley KM, editors. Current and emerging issues in cancer pain: research and practice. New York: Raven Press, Ltd. 1993. p. 331. 50.
Foley KM. The relationship of pain and symptom management to patient requests for physician-assisted suicide. J Pain Symptom Manage. 1991;6(5):289-97. [pmid: 1856503].
Forrest WH Jr, Brown BW Jr, Brown CR, Defalque R, Gold M, Gordon HE, James KE, Katz J, Mahler DL, Schroff P, Teutsch G. Dextroamphetamine with morphine for the treatment of postoperative pain. N Engl J Med. 1977;296(13):712-5. [pmid: 320478].
Fowler-Kerry S. Adolescent oncology survivors' recollection of pain. In: Tyler DC, Krane EJ, editors. First International Pain Symposium, Seattle, Washington, July 1988. Pediatric pain. Vol. 15. Advances in pain research and therapy. New York: Raven Press, Ltd. 1990:p. 365-72.
France RD. The future for antidepressants: treatment of pain. Psychopathology. 1987;20(suppl:1):99-113.
Fraser HM, Chapman V, Dickenson AH. Spinal local anaesthetic actions on afferent evoked responses and wind-up of nociceptive neurones in the rat spinal cord: combination with morphine produces marked potentiation of antinociception. Pain. 1992;49:33-41. [pmid: 1594281].
Freeman HP, Wasfie TJ. Cancer of the breast in poor black women. Cancer. 1989;63(12):2562-9. [pmid: 2720605].
French LA, Galicich JH. The use of steroids for control of cerebral edema. Clin Neurosurg. 1964;10:212-23. [pmid: 14095874].
Fultz JM, Sonay EC. Guidelines for the management of hospitalized narcotic addicts. Ann Intern Med. 1975;82(6):815-8. [pmid: 1138596].
Galasko CSB. Skeletal metastases and mammary cancer. Ann Roy Surg Engl. 1972;50:2-28.
Galer BS, Coyle N, Pasternak GW, Portenoy RK. Individual variability in the response to different opioids: report of five cases. Pain. 1992;49:87-91. [pmid: 1375728].
Gauvain-Piquard A, Rodary C, Rezvani A, Lemerle J. Pain in children aged 2-6 years: a new observational rating scale elaborated in a pediatric oncology unit—preliminary report. Pain. 1987;31(2):177-88.
Gerbershagen HU. Neurolysis. Subarachnoid neurolytic blockade. Acta Anaesthesiol Belg. 1981;32(1):44-57.
Gilbert RW, Kim JH, Posner JB. Epidural spinal cord compression from metastatic tumor: diagnosis and treatment. Ann Neurol. 1978;3(1):40-51. [pmid: 655653].
Gildenberg PL. Myelotomy and percutaneous cervical cordotomy for the treatment of cancer pain. Appl Neurophysiol. 1984;47(4-6):208-15. [pmid: 6599598].
Giorgi C, Broggi G. Surgical treatment of glossopharyngeal neuralgia and pain from cancer of the nasopharynx. A 20-year experience. J Neurosurg. 1984;61(5);952-5. [pmid: 6491739].
Glare P, Lickiss JN. Unrecognized constipation in patients with advanced cancer: a recipe for therapeutic disaster. J Pain Symptom Manage. 1992;7(6):369-71. [pmid: 1517653].
Glazier HS. Potentiation of pain relief with hydroxyzine: a therapeutic myth?. In: Thompson DF, editor. Therapeutic controversies. DICP Ann Pharmacother. 1990;24:484-8. [pmid: 2188436].
Goisis A, Gorini M, Ratti R, Luliri P. Application of a WHO protocol on medical therapy for oncologic pain in an internal medicine hospital. Tumori. 1989;75:470-2. [pmid: 2481351].
Gol A. Relief of pain by electrical stimulation of the septal area. J Neurol Sci. 1967;5(1):115-20. [pmid: 6061755].
Gonzales GR, Payne R, Foley KM, Portenoy RK. Prevalence and characteristics of brachial plexopathy in a large cancer center: a retrospective study. Third Annual Bristol-Meyers Pain Research Symposium, Seattle. 1992.
Gracely RH, Wolskee PJ. Semantic functional measurement of pain: integrating perception and language. Pain. 1983;15(4):389-98. [pmid: 6866537].
Graffam S, Johnson A. A comparison of two relaxation strategies for the relief of pain and its distress. J Pain Symptom Manage. 1987;2(4):229-31. [pmid: 3312428].
Greenberg HS, Deck MD, Vikram B, Chu FC, Posner JB. Metastasis to the base of the skull: clinical findings in 43 patients. Neurology. 1981;31(5):530-7. [pmid: 6972014].
Greenberg HS, Kim JH, Posner JB. Epidural spinal cord compression from metastatic tumor: results with a new treatment protocol. Ann Neurol. 1980;8(4):361-6. [pmid: 7436380].
Greenwald HP, Bonica JJ, Bergner M. The prevalence of pain in four cancers. Cancer. 1987;60(10):2563-9. [pmid: 2444328].
Grond S, Zech D, Schug SA, Lynch J, Lehmann KA. Validation of World Health Organization guidelines for cancer pain relief during the last days and hours of life. J Pain Symptom Manage. 1991;6(7):411-22. [pmid: 1940485].
Grossman SA, Sheidler VR, Swedeen K, Mucenski J, Piantadosi S. Correlation of patient and caregiver ratings of cancer pain. J Pain Symptom Manage. 1991;6(2):53-7. [pmid: 2007792].
Gybels J. The role of spinal cord stimulation in contemporary pain management: a commentary. APS Journal Summer. 1993;2(2):100-2.
Gybels JM, Sweet WH. Neurosurgical treatment of persistent pain. 1989.
Hagen NA, Foley KM, Cerbone DJ, Portenoy RK, Inturrisi CE. Chronic nausea and morphine-6-glucuronide. J Pain Symptom Manage. 1991;6(3):125-8. [pmid: 2016556].
Hall EJ. Nine decades of radiobiology: is radiation therapy any better for it?. Cancer. 1993;71:3753-66. [pmid: 8490926].
Hammes BJ, Cain JM. The ethics of pain management for cancer patients: case studies and analysis. J Pain Symptom Manage in press.
Hanks GW, Twycross RG, Lloyd JW. Unexpected complication of successful nerve block. Morphine induced respiratory depression precipitated by removal of severe pain. Anaesthesia. 1981;36(1):37-9. [pmid: 6894066].
Hargreaves KM, Joris JL. The peripheral analgesic effects of opioids. APS Journal. 1993;2(1):51-9.
Hayashi S. Der einfluss del ultraschallwellen und utrakurtzwellen auf den maligen tumor. Jpn J Med Sci Biophy. 1940;6.
Health and Public Policy Committee, American College of Physicians. Drug therapy for severe, chronic pain in terminal illness. Ann Intern Med. 1983;99(6):870-3. [pmid: 6139970].
Helig S. The San Francisco Medical Society Euthanasia Survey: results and analysis. SF Med. 1988;61:24-34.
Hendler CS, Redd WH. Fear of hypnosis: the role of labeling in patients' acceptance of behavioral interventions. Behav Ther. 1986;17(1):2-13.
Hendrickson M, Myre L, Johnson DG, Matlak ME, Black RE, Sullivan JJ. Postoperative analgesia in children: a prospective study in intermittent intramuscular injection versus continuous intravenous infusion of morphine. J Pediatr Surg. 1990;25(2):185-91. [pmid: 2303987].
Hertzka RE, Gauntlett IS, Fisher DM, Spellman MJ. Fentanyl-induced ventilatory depression: effects of age. Anesthesiology. 1989;70(2):213-8. [pmid: 2913858].
Hester NO. Comforting the child in pain. In: Funk SG, Tornquist EM, Champagne MT, Copp LA, Weise RA, editors. Key aspects of comfort: management of pain, fatigue, and nausea. New York: Springer Publishing Co. 1989:p. 290-8.
Hester NO, Barcus CS. Assessment and management of pain in children. Pediatr: Nurs Update. 1986;1:1-8.
Hester NO, Foster R, Kristensen K. Measurement of pain in children: generalizability and validity of the Pain Ladder and the Poker Chip Tool. In: Tyler DC, Krane EJ, editors. Pediatric pain. Vol. 15. Advances in pain research and therapy. New York: Raven Press, Ltd. 1990:p. 79-84.
Hester NO, Foster RL. Cues nurses and parents use in making judgments about children's pain. Pain. 1990;(suppl.5).
Hester NO, Foster RL, Beyer JE. Clinical judgment in assessing children's pain. In: Watt-Watson JH, Donovan MI, editors. Pain management: nursing perspective. St. Louis: Mosby-Yearbook, Inc. 1992:p. 236-94.
Hester NO, Foster RL, Kristensen K, Bergstrom L. Measurement of children's pain by children, parents, and nurses: psychometric and clinical issues related to the Poker Chip Tool and the Pain Ladder. Final grant report. Generalizability of procedures assessing pain in children. 1989.
Hill CS. A review and commentary on the negative influence of licensing and disciplinary boards and drug enforcement agencies on pain treatment with opioid analgesics. J Pharm Care in Pain & Symptom Control. 1993;1(1):33-50.
Hill HF, Chapman CR, Kornell JA, Sullivan KM, Saeger LC, Bendetti C. Self-administration of morphine in bone marrow transplant patients reduces drug requirement. Pain. 1990;40(2):121-9. [pmid: 2308758].
Hiraga K, Mizuguchi T, Takeda F. The incidence of cancer pain and improvement of pain management in Japan. Postgrad Med. 1991;67(suppl.):S14-25.
Hodes RL. Cancer patients' needs and concerns when using narcotic analgesics. In: Hill CS Jr, Fields WS, editors. Drug treatment of cancer pain in a drug-oriented society. 1989;Vol. 11. Advances in pain research and therapy. New York: Raven Press, Ltd:p. 91-9.
Hodsman NB, Burns J, Blyth A, Kenny GN, McArdle CS, Rotman H. The morphine sparing effects of diclofenac sodium following abdominal surgery. Anaesthesia. 1987;42(9):1005-8. [pmid: 3118730].
Hogan Q, Haddox JD, Abram S, Weissman D, Taylor ML, Janjan N. Epidural opiates and local anesthetics for the management of cancer pain. Pain. 1991;46(3):271-9. [pmid: 1758711].
Holland JC, Rowland J, editors. Handbook of psychooncology: psychological care of the patient with cancer. New York: Oxford University Press. 1989.
Horan JJ, Laying FC, Pursell CH. Preliminary study of effects of "in vivo" emotive imagery on dental discomfort. Percept Mot Skills. 1976;42(1):105-6. [pmid: 768895].
Horowitz S, Patwardhan R, Marcus E. Hepatotoxic reactions associated with carbamazepine therapy. Epilepsia. 1988;29(2):149-54. [pmid: 3280305].
Hoskin PJ. Scientific and clinical aspects of radiotherapy in the relief of bone pain. Cancer Surv. 1988;7(1):69-86. [pmid: 3289744].
Houde RW. Methods for measuring clinical pain in humans. Acta Anaesthesiol Scand. 1982;74(suppl.):25-9.
Houde RW. Analgesic effectiveness of the narcotic agonist-antagonists. Br J Clin Pharmac. 1979;7:297S-308S.
Houde RW. The use and misuse of narcotics in the treatment of chronic pain. In: Bonica JJ, editor. International Symposium on Pain. 1974;Vol. 4 Advances in Neurology. New York: Raven Press, Ltd:p. 527-36.
Howland JS, Baker MG, Poe T. Does patient education cause side effects? A controlled trial. J Fam Pract. 1990;31(1):62-4. [pmid: 2193996].
International Association for the Study of Pain, Subcommittee on Taxonomy. Part II. Pain terms: a current list with definitions and notes on usage. Pain. 1979;6:249-52 [updated 1982, 1986]. [pmid: 460932].
Inturrisi CE, Colburn WA, Kaiko RF, Houde RW, Foley KM. Pharmacokinetics and pharmacodynamics of methadone in patients with chronic pain. Clin Pharmacol Ther. 1987;41:392-401. [pmid: 3829576].
Ischia S, Ischia A, Luzzani A, Toscano D, Steele A. Results up to death in the treatment of persistent cervico-thoracic (Pancoast) and thoracic malignant pain by unilateral percutaneous cervical cordotomy. Pain. 1985;21(4):339-55. [pmid: 3858785].
Ischia S, Ischia A, Polati E, Finco G. Three posterior percutaneous celiac plexus block techniques. A prospective, randomized study in 61 patients with pancreatic cancer pain. Anesthesiology. 1992;76(4):534-40. [pmid: 1550278].
Ischia S, Luzzani A, Polati E. Retrogasserian glycerol injection: a retrospective study of 112 patients. Clin J Pain. 1990;6(4):291-6. [pmid: 2135029].
Jacox A, Carr D, Payne R, et al. Managing Cancer Pain: Patient Guide. Clinical Practice Guideline Number 9 (Adult version—English). Rockville, MD: US Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research. AHCPR Publication No. 93-0595. 1994;March.
Jacox A, Carr D, Payne R, et al. Managing of Cancer Pain: Patient Guide. Clinical Practice Guideline Number 9 (Adult version -- Spanish). Rockville, MD. AHCPR Publication. No. 93-0596, in press.
Jaeckle KA, Young DF, Foley KM. The natural history of lumbosacral plexopathy in cancer. Neurology. 1985;35(1):8-15. [pmid: 2981417].
Jaffe JH. Drug addiction and drug abuse. In: Gilman AG, Goodman LS, Rall TW, Murad F, editors. The pharmacological basis of therapeutics. 7th ed. New York: Macmillan Publishers. 1985:p. 532-81.
Janjan NA, Weissman DE, Pahule A. Improved pain management with daily nursing intervention during radiation therapy for head and neck carcinoma. Int J Radiat Oncol Biol Phys. 1992;23(3):647-52. [pmid: 1612966].
Jay SM, Elliott CH, Ozolins M, Olson RA, Pruitt SD. Behavioral management of children's distress during painful medical procedures. Behav Res Ther. 1985;23(5):513-20. [pmid: 4051924].
Jeff asks about cancer pain. 1990.
Johnson JE, Rice VH, Fuller SS, Endress MP. Sensory information, instruction in a coping strategy, and recovery from surgery. Res Nurs Health. 1978;1(1):4-17. [pmid: 349614].
Joranson DE. Federal and state regulation of opioids. J Pain Symptom Manage. 1990;5(1 suppl.):S12-23. [pmid: 1969888].
Joranson DE. Are health care reimbursement policies a barrier to acute and cancer pain management?. J Pain Symptom Manage in press.
Joranson DE, Cleeland CS, Weissman DE, Gilson AM. Opioids for chronic cancer and non-cancer pain: a survey of state medical board members. Federation Bulletin: The Journal of Medical Licensure and Discipline. 1992;79(4):15-49.
Joshi JH, de Jongh CA, Schnaper N, Fortner CL, Wiernik PH. Amphetamine therapy for enhancing the comfort of terminally ill patients with cancer. 18th Annual Meeting of the American Society of Clinical Oncology. 1982 Apr 25-27;1:>55.
Kaiko RF. Age and morphine analgesia in cancer patients with post-operative pain. Clin Pharmacol Ther. 1980;28(6):823-6. [pmid: 7438698].
Kaiko RF, Foley KM, Grabinski PY, Heidrich G, Rogers AG, Inturrisi CE, Reidenberg MM. Central nervous system excitatory effects of meperidine in cancer patients. Ann Neurol. 1983;13(2):180-5. [pmid: 6187275].
Kaiko RF, Kanner R, Foley KM, Wallenstein SL, Canel AM, Rogers AG, Houde RW. Cocaine and morphine interaction in acute and chronic cancer pain. Pain. 1987;31(1):35-45. [pmid: 3320880].
Kallos T, Caruso FS. Respiratory effects of butorphanol and pethidine. Anaesthesia. 1979;34(7):633-7. [pmid: 517715].
Kane RL, Ouslander JG, Abrass IB, editors. Essentials of clinical geriatrics. 1989.
Kanner R. Post-surgical pain syndromes. In: Management of cancer pain: syllabus of the postgraduate course, Memorial Sloan-Kettering Cancer Center, 1985 Nov 14-16. New York: Memorial Sloan-Kettering Cancer Center. 1985:p. 65-72.
Kanner RM, Foley KM. Patterns of narcotic drug use in a cancer pain clinic. In: Research development in drug and alcohol use. Ann NY Acad Sci. 1981;362:161-72. [pmid: 6114697].
Kanner RM, Portenoy RK. Unavailability of narcotic analgesics for ambulatory cancer patients in New York City. J Pain Symptom Manage. 1986;1(2):87-9. [pmid: 2877034].
Kapelushnik J, Koren G, Solh H, Greenberg M, DeVeber L. Evaluating the efficacy of EMLA in alleviating pain associated with lumbar puncture; comparison of open and double-blinded protocols in children. Pain. 1990;42(1):31-4. [pmid: 2234995].
Katz ER, Kellerman J, Ellenberg L. Hypnosis in the reduction of acute pain and distress in children with cancer. J Pediatr Psychol. 1987;12(3):379-94. [pmid: 3479547].
Katz J, Levin AB. Treatment of diffuse metastatic cancer pain by instillation of alcohol into the sella turcica. Anesthesiology. 1977;46(2):115-21. [pmid: 319706].
Kaye BR. Rheumatologic manifestations of infection with human immunodeficiency virus (HIV). Ann Intern Med. 1989;111(2):158-67. [pmid: 2662849].
Keller M. A retrospective review of patients receiving continuous morphine infusion. PRN Forum. 1984;3:5-6.
Kelly JB, Payne R. Pain syndromes in the cancer patient. Neurol Clin. 1991;9(4):937-53. [pmid: 1758433].
Kerr IG, Sone M, Deangelis C, Iscoe N, MacKenzie R, Schueller T. Continuous narcotic infusion with patient-controlled analgesia for chronic cancer pain in outpatients. Ann Intern Med. 1988;108(4):554-7. [pmid: 2894791].
Khurana RC. Treatment of painful diabetic neuropathy with trazadone. JAMA. 1983;250. [pmid: 6887456].
Kishore-Kumar R, Max MB, Schafer SC, Gaughan AM, Smoller B, Gracely RH, Dubner R. Desipramine relieves postherpetic neuralgia. Clin Pharmacol Ther. 1990;47(3):305-12. [pmid: 2178851].
Kisner C, Colby LA. Range of motion. In: Kisner C, Colby LA, editors. Therapeutic exercise: foundations and techniques. Philadelphia: FA Davis Co. 1985:p. 19-65.
Koehntop DE, Rodman JH, Brundage DM, Hegland MG, Buckley JJ. Pharmacokinetics of fentanyl in neonates. Anesth Analg. 1986;65(3):227-32. [pmid: 3954090].
Kohl HW, LaPorte RE, Blair SN. Physical activity and cancer. An epidemiological perspective. Sports Med. 1988;6:222-37. [pmid: 3067310].
Kolassa M. Guidelines for clinicians in discerning and comparing the prices of pharmaceutical agents. J Pain Symptom Manage in press.
Koren G, Butt W, Chinyanga H, Soldin S, Tan YK, Pape K. Postoperative morphine infusion in newborn infants: assessment of disposition characteristics and safety. J Pediatr. 1985;107(6):963-7. [pmid: 4067757].
Kori SH, Foley KM, Posner JB. Brachial plexus lesions in patients with cancer: 100 cases. Neurology. 1981;31(1):45-50. [pmid: 6256684].
Kovar PA, Allegrante JP, MacKenzie R, Peterson MGE, Gutin B, Charlson ME. Supervised fitness walking in patients with osteoarthritis of the knee. A randomized, controlled trial. Ann Intern Med. 1992;116(7):529-34. [pmid: 1543305].
Krames ES, Gershow J, Glassberg A, Kenefick T, Lyons A, Taylor P, Wilkie D. Continuous infusion of spinally administered narcotics for the relief of pain due to malignant disorders. Cancer. 1985;56(3):696-702. [pmid: 3839163].
Kreek MJ, Garfield JW, Gutjahr CL, Giusti LM. Rifampin-induced methadone withdrawal. N Engl J Med. 1976;294(20):1104-6. [pmid: 1256526].
Kuban DA, Schellhammer PF, el-Mahdi AM. Hemibody irradiation in advanced prostatic carcinoma. Urol Clin North Am. 1991;18(1):131-7. [pmid: 1704159].
Kuttner L. Favorite stories: a hypnotic pain-reduction technique for children in acute pain. Am J Clin Hypn. 1988;30(4):289-95. [pmid: 3364392].
Kvinesdal B, Molin J, Froland A, Gram LF. Imipramine treatment of painful diabetic neuropathy. JAMA. 1984;251(13):1727-30. [pmid: 6366276].
Lahuerta J, Lipton S, Miles J, Wells CB. Update on percutaneous cervical cordotomy and pituitary alcohol neuroadenolysis: an audit of our recent results and complications. In: Lipton S, Miles J, editors. Persistent pain: modern methods of treatment. Vol 5. Orlando FL: Grune & Stratton. 1985:p. 197-223.
Lahuerta J, Lipton S, Wells JC. Percutaneous cervical cordotomy: results and complications in a recent series of 100 patients. Ann R Coll Surg Engl. 1985;67(1):41-4. [pmid: 2578269].
Lasagna L, DeKornfeld TJ. Methotrimeprazine: a new phenothiazine derivative with analgesic properties. JAMA. 1961;178(9):887-90. [pmid: 14462565].
Lawton PA, Maher EJ. Treatment strategies for advanced and metastatic cancer in Europe. Radiother Oncol. 1991;22(1):1-6. [pmid: 1947207].
Lazorthes Y, Verdie JC, Bastide R, Lavados A, Descouens D. Spinal versus intraventricular chronic opiate administration with implantable drug delivery devices for cancer pain. Appl Neurophysiol. 1985;48(1-6):234-41. [pmid: 3841799].
LeBaron S, Zeltzer L. Assessment of acute pain and anxiety in children and adolescents by self-reports, observer reports, and a behavior checklist. J Consult Clin Psychol. 1984;52(5):729-38. [pmid: 6501658].
Lebovits AH, Lefkowitz M, McCarthy D, Simon R, Wilpon H, Jung R, Fried E. The prevalence and management of pain in patients with AIDS: a review of 134 cases. Clin J Pain. 1989;5:245-8. [pmid: 2520410].
Lee MHM, Itoh M, Yang GW, Eason AL. Physical therapy and rehabilitation medicine. In: Bonica JJ, editor. The management of pain. 1990;2nd ed. Vol. 2. Philadelphia: Lea & Febiger:p. 1769-88.
Lehmann JF, de Lateur BJ. Therapeutic heat. In: Lehmann JF, editor. Therapeutic heat and cold. 4th ed. Baltimore, MD: Williams & Wilkins. 1990:p. 417-581.
Lema MJ, Myers DP, de Leon-Casasola O, Penetrante R. Pleural phenol therapy for the treatment of chronic esophageal cancer pain. Reg Anesth. 1992;17:166-70. [pmid: 1606100].
Lesko LM, Fleishman S. Treatment and support in confusional states. Recent Results Cancer Res. 1991;121:378-92. [pmid: 1857878].
Levin AB, Katz J, Benson RC, Jones AG. Treatment of pain of diffuse metastatic cancer by stereotactic chemical hypophysectomy: long term results and observations on mechanism of action. Neurosurgery. 1980;6(3):258-62. [pmid: 6991970].
Levin DN, Cleeland CS, Dar R. Public attitudes toward cancer pain. Cancer. 1985;56(9):2337-9. [pmid: 2865000].
Levy MH. Integration of pain management into comprehensive cancer care. Cancer. 1989;63:2328-35. [pmid: 2470492].
Levy MH. Constipation and diarrhea in cancer patients. Cancer Bull. 1991;43(5):412-22.
Lewington VJ, McEwan AJ, Ackery DM, Bayly RJ, Keeling DH, Macleod PM, Porter AT, Zivanovic MA. A prospective, randomised double-blind crossover study to examine the efficacy of strontium-89 in pain palliation in patients with advanced prostate cancer metastatic to bone. Eur J Cancer. 1991;27(8):954-8. [pmid: 1716935].
Lindstrom P, Lindblom U. The analgesic effect of tocainide in trigeminal neuralgia. Pain. 1987;28:45-50. [pmid: 3103044].
Lipowski ZJ. Delirium (acute confusional states). JAMA. 1987;258(13):1789-92. [pmid: 3625989].
Lipton S, Miles J, Williams N, Jones NB. Pituitary injection of alcohol for widespread cancer pain. Pain. 1978;5(1):73-82. [pmid: 79162].
Lynn AM, Slattery JT. Morphine pharmacokinetics in early infancy. Anesthesiology. 1987;66(2):136-9. [pmid: 3813075].
Maher EJ, Coia L, Duncan G, Lawton PA. Treatment strategies in advanced and metastatic cancer: differences in attitude between the USA, Canada and Europe. Int J Radiat Oncol Biol Phys. 1992;23(1):239-44. [pmid: 1572821].
Malawer MM, Delaney TF. Treatment of metastatic cancer to bone. In: DeVita VT Jr, Hellman S, Rosenberg SA, editors. Cancer: principles & practice of oncology. 3rd ed. Vol. 2. Philadelphia: JB Lippincott. 1989:p. 2298-316.
Maltbie AA, Cavenar JO Jr, Sullivan JL, Hammett EB, Zung WW. Analgesia and haloperidol: a hypothesis. J Clin Psychiatry. 1979;40(7):323-6. [pmid: 222741].
Mantell JE, Alexander ES, Kleiman MA. Social work and self-help groups. Health Soc Work. 1976;1(1):86-100. [pmid: 976859].
Marchand S. Nervous system stimulation for pain relief. APS Journal. 1993;2(2):103-6.
Marks RM, Sachar EJ. Undertreatment of medical inpatients with narcotic analgesics. Ann Intern Med. 1973;78(2):173-81. [pmid: 4683747].
Martin WR. Pharmacology of opioids. Pharmacol Rev. 1984;35.
Massie MJ, Holland J, Glass E. Delirium in terminally ill cancer patients. Am J Psychiatry. 1983;140(8):1048-50. [pmid: 6869591].
Massie MJ, Holland JC. Depression and the cancer patient. J Clin Psychiatry. 1990;51(suppl.):12-17. [pmid: 2195008].
Massie MJ, Holland JC. The cancer patient with pain: psychiatric complications and their management. Med Clin North Am. 1987;71(2):243-58. [pmid: 3546980].
Mastrovito R, Moynihan RT, Parsonnet L. Self-help and mutual support programs. In: Holland JC, Rowland JH, editors. Handbook of psychooncology: psychological care of the patient with cancer.New York: Oxford University Press. 1989:p. 502-7.
Maves TJ, Gebhart GF. Antinociceptive synergy between intrathecal morphine and lidocaine during visceral and somatic nociception in the rat. Anesthesiology. 1992;76:91-9. [pmid: 1729942].
Max MB. Improving outcomes of analgesic treatment: is education enough?. Ann Intern Med. 1990;113(11):885-9. [pmid: 2240903].
Max MB, Culnane M, Schafer SC, Gracely RH, Walther DJ, Smoller B, Dubner R. Amitriptyline relieves diabetic neuropathy pain in patients with normal or depressed mood. Neurology. 1987;37(4):589-96. [pmid: 2436092].
Max MB, Inturrisi CE, Kaiko RF, Grabinski PY, Li CH, Foley KM. Epidural and intrathecal opiates: cerebrospinal fluid and plasma profiles in patients with chronic cancer pain. Clin Pharmacol Ther. 1985;38:631-41. [pmid: 2415286].
Max MB, Schafer SC, Culnane M, Smoller B, Dubner R, Gracely RH. Amitriptyline, but not lorazepam, relieves postherpetic neuralgia. Neurology. 1988;38(9):1427-32. [pmid: 3412591].
Maxon HR III, Schroder LE, Thomas SR, Hertzberg VS, Deutsch EA, Scher HI, Samaratunga RC, Libson KF, Williams CC, Moulton JS, Schneider HJ. Re-186(Sn) HEDP for treatment of osseous metastases: initial clinical experience in 20 patients with hormone-resistant prostate cancer. Radiology. 1990;176(1):155-9. [pmid: 1693784].
Maxon HR III, Smith HS. Radioiodine-131 in the diagnosis and treatment of metastatic well-differentiated thyroid cancer. Endocrinol Metab Clin North Am. 1990;19(3):685-718. [pmid: 2261912].
Mayer DJ, Liebeskind JC. Pain reduction by focal electrical stimulation of the brain: an anatomical and behavioral analysis. Brain Res. 1974;68:73-93. [pmid: 4549764].
Mayer DK. Non-pharmacologic management of pain in the person with cancer. J Adv Nurs. 1985;10(4):325-30. [pmid: 3900169].
McCaffery M, Beebe A. Pain: clinical manual for nursing practice. 1989.
McCaffery M, Martin L, Ferrell BR. Analgesic administration via rectum or stoma. ET Nurs. 1992;19(4):114-21.
McCaffery M, Wolff M. Pain relief using cutaneous modalities, positioning, and movement. In: Turk DC, Feldman CS, editors. Special issue: noninvasive approaches to pain management in the terminally ill. Hospice J 1992;8(1-2):121-53. New York: Haworth Press.
McCaul KD, Malott JM. Distraction and coping with pain. Psychol Bull. 1984;95(3):516-33. [pmid: 6399756].
McGivney WT, Crooks GM. The care of patients with severe chronic pain in terminal illness. JAMA. 1984;251(9):1182-8. [pmid: 6141302].
McGrath PA. The plasticity and complexity of the nociceptive system. In: McGrath PA, editor. Pain in children: nature, assessment, and treatment. New York: The Guilford Press. 1990a:p. 88-110.
McGrath PA, editor. Pain in children: nature, assessment, and treatment. 1990b.
McGrath PA, de Veber LL, Hearn MT. Multidimensional pain assessment in children. In: Fields HL, Dubner R, Cervero F, editors. Proceedings of the Fourth World Congress on Pain, Seattle. 1985;Vol. 9. Advances in pain research and therapy. New York: Raven Press, Ltd:p. 387-93.
McGrath PJ, Unruh AM. Pain in children and adolescents. 1987.
McKinney's Public Health Law, Sec. 3302 (1).
Meglio M, Cioni B. Personal experience with spinal cord stimulation in chronic pain management. In: Gildenberg PL, et al., editors. Proceedings of the eighth meeting of the World society and fifth meeting of the European society, Zurich, Switzerland, July 9-11. 1982. 1981;Vol. 9:p. 195-200.
Meglio M, Cioni B, Rossi GF. Spinal cord stimulation in management of chronic pain. A 9-year experience. J Neurosurg. 1989;70(4):519-24. [pmid: 2538588].
Meignier M, Souron R, Le Neel JC. Postoperative dorsal epidural analgesia in the child with respiratory disabilities. Anesthesiology. 1983;59(5):473-5. [pmid: 6638559].
Melding PS. Is there such a thing as geriatric pain?. Pain. 1991;46(2):119-21. [pmid: 1749634].
Melzack R. The tragedy of needless pain. Sci Am. 1990;262(2):27-33. [pmid: 2296714].
Mercadante S. Celiac plexus block versus analgesics in pancreatic cancer pain. Pain. 1993;52:187-92. [pmid: 8455966].
Messerli ML, Garamendi C, Romano J. Breast cancer: information as a technique of crisis intervention. Am J Orthopsychiatry. 1980;50(4):728-31. [pmid: 7425110].
Meyerson BA. Central nervous stimulation for cancer pain: possible methods of manipulating the physiology of pain control. In: Bonica JJ, Ventafridda V, Pagni CA, editors. Management of superior pulmonary sulcus syndrome (Pancoast Syndrome). Vol. 4, Advances in pain research and therapy. New York: Raven Press, Ltd. 1982:p. 149-64.
Meyerson BA, Boethius J, Carlsson AM. Percutaneous central gray stimulation for cancer pain. Appl Neurophysiol. 1978;41(1-4):57-65. [pmid: 310285].
Miaskowski C, Donovan M. Implementation of the American Pain Society Quality Assurance Standards for Relief of Acute Pain and Cancer Pain in oncology nursing practice. Oncol Nurs Forum. 1992;19(3):411-5. [pmid: 1594463].
Miaskowski C, Jacox A, Hester NO, Ferrell B. Interdisciplinary guidelines for the management of acute pain: implications for quality improvement. J Nurs Care Qual. 1992;7(1):1-6. [pmid: 1446060].
Michlovitz SL. Diathermy and pulsed electromagnetic fields. In: Michlovitz SL, editor. Thermal agents in rehabilitation. 2nd ed. Philadelphia: FA Davis and Co. 1990.
Middaugh SJ, Levin RB, Kee WG, Barchiesi FD, Roberts JM. Chronic pain: its treatment in geriatric and younger patients. Arch Phys Med Rehabil. 1988;69(12):1021-6. [pmid: 3214260].
Miles J, Lipton S, Hayward M, Bowsher D, Mumford J, Molony V. Pain relief by implanted electrical stimulators. Lancet. 1974;1(861):777-9. [pmid: 4132710].
Miser AW. Management of pain associated with childhood cancer. In: Schechter NL, Berde CB, Yaster M, editors. Pain in infants, children, and adolescents. Baltimore: Williams & Wilkins. 1993:p. 411-24.
Miser AW, Ayesh D, Broda E, McCalla J, Steinberg SM, Wall R, Jelenich S, Lees DE, Wilkinson TK, Miser JS. Use of a patient-controlled device for nitrous oxide administration to control procedure-related pain in children and young adults with cancer. Pain. 1988;4:5-10.
Miser AW, Dothage JA, Wesley RA, Miser JS. The prevalence of pain in a pediatric and young adult cancer population. Clin J Pain. 1987;29(1):73-83.
Miser AW, Miser JS. The use of oral methadone to control moderate and severe pain in children and young adults with malignancy. Clin J Pain. 1986;1:243-8.
Miser AW, Miser JS. The treatment of cancer pain in children. Pediatr Clin North Am. 1989;36(4):979-99. [pmid: 2569186].
Miser AW, Moore L, Greene R, Gracely RH, Miser JS. Prospective study of continuous intravenous and subcutaneous morphine infusions for therapy-related or cancer-related pain in children and young adults with cancer. Clin J Pain. 1986;2:101-6.
Mishel MH. Perceived uncertainty and stress in illness. Res Nurs Health. 1984;7(3):163-71. [pmid: 6567948].
Moinpour CM, Chapman CR. Pain management and quality of life in cancer patients. In: Lehmann RKA, Zech D, editors. Transdermal fentanyl: a new approach to prolonged pain control. Berlin: Springer-Verlag. 1991:p. 42-63.
Morris HG, Sherman NA, McQuain C, Goldlust MB, Chang SF, Harrison LI. Effects of salsalate (nonacetylated salicylate) and aspirin on serum prostaglandins in humans. Ther Drug Monit. 1985;7:435-8. [pmid: 3866409].
Moulin DE, Kreeft JH, Murray-Parsons N, Bouquillon AI. Comparison of continuous subcutaneous and intravenous hydromorphone infusion for management of cancer pain. Lancet. 1991;337(8739):465-8. [pmid: 1704089].
Munro S, Mount B. Music therapy in palliative care. Can Med Assoc J. 1978;119(9):1029-34. [pmid: 84704].
Nagashima H, Karamanian A, Malovany R, Radnay P, Ang M, Koerner S, Foldes FF. Respiratory and circulatory effects of intravenous butorphanol and morphine. Clin Pharmacol Ther. 1976;19(6):738-45. [pmid: 773585].
Nahata MC, Clotz MA, Krogg EA. Adverse effects of meperidine, promethazine, and chlorpromazine for sedation in pediatric patients. Clin Pediatr (Phila). 1985;24(10):558-60. [pmid: 4028614].
Nahata MC, Miser AW, Miser JS, Reuning RH. Analgesic plasma concentrations of morphine in children with terminal malignancy receiving a continuous subcutaneous infusion of morphine sulfate to control severe pain. Pain. 1984;18(2):109-14. [pmid: 6200819].
National Cancer Institute. NCI Workshop on Cancer Pain. Sept 14-15. 1990.
National Institutes of Health Consensus Development Conference. The integrated approach to the management of pain. J Pain Symptom Manage. 1987;2(1):35-44. [pmid: 3644857].
Newman RG. The need to redefine "addiction. ". N Engl J Med. 1983;308(18):1096-8. [pmid: 6835323].
Nielsen OS, Munro AJ, Tannock IF. Bone metastases: pathophysiology and management policy. J Clin Oncol. 1991;9(3):509-24. [pmid: 1705581].
Nittner K. Stimulation of conus-epiconus with pisces—further indications. Acta Neurochir (Wien). 1980;(suppl.);30:311-6.
North RB. The role of spinal cord stimulation in contemporary pain management. APS Journal. 1993;2(2):91-9.
The Nurses' Association of the American College of Obstetricians and Gynecologists (NAACOG) Committee on Practice. OGN nursing practice resource. Prevention, recognition, and management of neonatal pain. Washington, DC: NAACOG. April:1991.
O'Neill WM, Sherrard JS. Pain in human immune deficiency virus disease: a review. Pain. 1993;54:3-14. [pmid: 8378101].
O'Young J, McPeek B. Quality of life variables in surgical trials. J Chron Dis. 1987;40(6):513-22. [pmid: 3298293].
Obbens EA, Hill CS, Leavens ME, Ruthenbeck SS, Otis F. Intraventricular morphine administration for control of chronic cancer pain. Pain. 1987;28(1):61-8. [pmid: 3822495].
Oda MAS, Schurman DJ. Monitoring of pathological fracture. In: Stoll BA, Parbhoo S, editors. Bone metastasis: monitoring and treatment. New York: Raven Press, Ltd. 1983:p. 271-88.
Olness K. Hypnosis in pediatric practice. Curr Probl Pediatr. 1981;12(2):1-47. [pmid: 7333133].
Onghena P, Van Houdenhove B. Antidepressant-induced analgesia in chronic non-malignant pain: a meta-analysis of 39 placebo-controlled studies. Pain. 1992;49(2):205-19. [pmid: 1535121].
Onofrio BM, Yaksh TL. Long-term pain relief produced by intrathecal morphine infusion in 53 patients. J Neurosurg. 1990;72:200-9. [pmid: 1688618].
Paice J. Personal communication. May 5, 1993.
Paice J. Resources in cancer pain management. Oncol Nurs Forum. 1990;17(4):587-90. [pmid: 2204887].
Patchell RA, Posner JB. Cancer and the nervous system. In: Holland JC, Rowland JH, editors. The handbook of psychooncology: psychological care of the patient with cancer. New York: Oxford University Press. 1989:p. 327-41.
Patel M, Gutzwiller F, Paccaud F, Marazzi A. A meta-analysis of acupuncture for chronic pain. Int J Epidemiol. 1989;18(4):900-6. [pmid: 2695475].
Patt RB. Cancer pain. 1993.
Payne R. Transdermal fentanyl: suggested recommendations for clinical use. J Pain Symptom Manage. 1992;7(suppl.3):S40-4. [pmid: 1517631].
Payne RC. Post-chemotherapy and post-radiation therapy pain syndromes. In: Management of cancer pain: syllabus of the postgraduate course, Memorial Sloan-Kettering Cancer Center. 1985 Nov 14-16:p. 73-93.
Pellock JM. Carbamazepine side effects in children and adults. Epilepsia. 1987;28(suppl.3):S64-S70. [pmid: 2961558].
Pfaff VK, Smith KE, Gowan D. The effects of music-assisted relaxation on the distress of pediatric cancer patients undergoing bone marrow aspirations. Child Health Care. 1989;18(4):232-6.
Pfalzer L. Physical agents and the patient with cancer. Clin Manage Phys Ther. 1992;12(4):83-6.
Pilowsky I, Hallett EC, Bassett DL, Thomas PG, Penhall RK. A controlled study of amitriptyline in the treatment of chronic pain. Pain. 1982;14(2):169-79. [pmid: 6757842].
Popkin MK, Callies AL, Mackenzie TB. The outcome of antidepressant use in the medically ill. Arch Gen Psychiatry. 1985;42(12):1160-3. [pmid: 4074108].
Portenoy RK. Continuous infusion of opioid drugs in the treatment of cancer pain: guidelines for use. J Pain Symptom Manage. 1986;1(4):223-8. [pmid: 3640796].
Portenoy RK. Continuous intravenous infusion of opioid drugs. Med Clin North Am. 1987;71(2):233-41. [pmid: 2881033].
Portenoy RK. Personal communication. June 15, 1993.
Portenoy RK. Practical aspects of pain control in the patient with cancer. CA Cancer J Clin. 1988;38(6):327-52. [pmid: 2460202].
Portenoy RK, Hagen NA. Breakthrough pain: definition, prevalence and characteristics. Pain. 1990;41(3):273-81. [pmid: 1697056].
Portenoy RK, Lipton RB, Foley KM. Back pain in the cancer patient: an algorithm for evaluation and management. Neurology. 1987;37(1):134-8. [pmid: 2948135].
Portenoy RK, Payne R. Acute and chronic pain. In: Lowinson JH, Ruiz P, Millman RB, editors. Substance abuse: a comprehensive textbook. 2nd ed. Baltimore: Williams & Wilkins. 1992:p. 691-721.
Portenoy RK, Southam MA, Gupta SK, Lapin J, Layman M, Inturrisi CE, Foley KM. Transdermal fentanyl for cancer pain. Repeated dose pharmacokinetics. Anesthesiology. 1993;78(1):36-43. [pmid: 8424569].
Poulter CA, Cosmatos D, Rubin P, Urtasun R, Cooper JS, Kuske RR, Hornback N, Coughlin C, Weigensberg I, Rotman M. A report of RTOG 8206: a phase III study of whether the addition of single dose hemibody irradiation to standard fractionated local field irradiation is more effective than local field irradiation alone in the treatment of symptomatic osseous metastases. Int J Radiat Oncol Biol Phys. 1992;23(1):207-14. [pmid: 1374061].
Powell KE, Thompson PD, Caspersen CJ, Kendrick JS. Physical activity and the incidence of coronary heart disease. Annu Rev Public Health. 1987;8:253-87. [pmid: 3555525].
Price P, Hoskin PJ, Easton D, Austin D, Palmer SG, Yarnold JR. Prospective randomised trial of single and multifraction radiotherapy schedules in the treatment of painful bony metastases. Radiother Oncol 1986. 6(4):247-55.
Puntillo KA. Pain experiences of intensive care unit patients. Heart Lung. 1990;19(5 Pt 1):526-33. [pmid: 2211161].
Purcell-Jones G, Dormon F, Sumner E. The use of opioids in neonates. A retrospective study of 933 cases. Anaesthesia. 1987;42(12):1316-20. [pmid: 3324818].
Raj PP. Practical management of pain. 2nd ed. St. Louis: Mosby Year Book. 1992.
Rawal M, Mollefors K, Axelsson K, Linga rdh G, Widman B. An experimental study of urodynamic effects of epidural morphine and of naloxone reversal. Anesth Analg. 1983;62:641-7. [pmid: 6859567].
Reading AE. The effects of psychological preparation on pain and recovery after minor gynecological surgery: preliminary report. J Clin Psychol. 1982;38(3):504-12. [pmid: 6213641].
Reeves JL, Redd WH, Storm FK, Minagawa RY. Hypnosis in the control of pain during hyperthermia treatment of cancer. In: Bonica JJ, Lindblom U, Iggo A, editors. Proceedings of the Third World Congress on Pain, Edinburgh. Vol. 5. Advances in pain research and therapy. New York: Raven Press, Ltd. 1983:p. 857-61.
Reich W. Encyclopedia of bioethics. New York: The Free Press. 1992.
Reynolds DV. Surgery in the rat during electrical analgesia induced by focal brain stimulation. Science. 1969;164:444-5. [pmid: 4887743].
Rhiner M, Ferrell BR, Ferrell BA, Grant MM. A structured non-drug intervention program for cancer pain. Cancer Practice. 1993;1(2):137-43. [pmid: 8324539].
Rimer B, Levy MH, Keintz MK, Fox L, Engstrom PF, MacElwee N. Enhancing cancer pain control regimens through patient education. Patient Educ Couns. 1987;10(3):267-77. [pmid: 10315745].
Robinson RG, Spicer JA, Preston DR, Wegst AV, Martin NL. Treatment of metastatic bone pain with strontium-89. Int J Rad Appl Instrum [B]. 1987;14(3):219-22. [pmid: 3667305].
Rodriguez M, Dinapoli RP. Spinal cord compression: with special reference to metastatic epidural tumors. Mayo Clin Proc. 1980;55(7):442-8. [pmid: 7382554].
Rodriguez-Bigas M, Petrelli NJ, Herrera L, West C. Intrathecal phenol rhizotomy for management of pain in recurrent unresectable carcinoma of the rectum. Surg Gynecol Obstet. 1991;173(1):41-4. [pmid: 1866669].
Rogers AG. The use of methotrimeprazine (Levoprome) in a patient sensitive to opioids and possible bowel shutdown. J Pain Symptom Manage. 1989;4(1):44-5. [pmid: 2703737].
Ross DM. Thought-stopping: a coping strategy for impending feared events. Issues Compr Pediatr Nurs. 1984;7(2-3):83-9. [pmid: 6378844].
Ross DM, Ross SA. Childhood pain: current issues, research, and management. Baltimore: Urban & Schwarzenberg. 1988.
Roth A, Kolaric K. Analgetic activity of calcitonin in patients with painful osteolytic metastases of breast cancer. Oncology. 1986;43:283-7. [pmid: 3531953].
Roth SH. Merits and liabilities of NSAID therapy. Rheum Dis Clin North Am. 1989;15(3):479-98. [pmid: 2672133].
Rusthoven JJ, Ahlgren P, Elhakim T, Pinfold P, Reid J, Stewart L, Feld R. Varicella-zoster infection in adult cancer patients. A population study. Arch Intern Med. 1988;148(7):1561-6. [pmid: 3382302].
Ryan EA. The effect of musical distraction on pain in hospitalized school-aged children. In: Funk SG, Tornquist EM, Champagne MT, Copp LA, Wiese RA, editors. Key aspects of comfort: management of pain, fatigue, and nausea. New York: Springer Publishing Co. 1989:p. 101-4.
Salazar OM, Rubin P, Hendrickson FR, Komaki R, Poulter C, Newall J, Asbell SO, Mohiuddin M, van Ess J. Single dose half-body irradiation for palliation of multiple bone metastases from solid tumors. Final Radiation Therapy Oncology Group report. Cancer. 1986;58(1):29-36. [pmid: 2423225].
Salmon JB, Finch PM, Lovegrove FT, Warwick A. Mapping of spread of epidural phenol in cancer pain patients by radionuclide admixture and epidural scintigraphy. Clin J Pain. 1992;8:18-22. [pmid: 1576415].
Savedra MC, Tesler MD, Holzemer WL, Ward JA. Adolescent Pediatric Pain Tool (APPT) preliminary user's manual. San Francisco: University of California. 1989; updated 1992.
Savedra MC, Tesler MD, Holzemer WL, Wilkie DJ, Ward JA. Pain location. Res Nurs Health. 1989;12(5). 307. 14. [pmid: 2798951].
Schechter NL. The undertreatment of pain in children: an overview. Pediatr Clin North Am. 1989;36(4):781-94. [pmid: 2666929].
Schechter NL, Weisman SJ, Rosenblum M, Beck A, Altman A, Quinn J, Conrad PF. Sedation for painful procedures in children with cancer using the fentanyl lollipop: a preliminary report. In: Tyler DC, Krane EJ, editors. Pediatric pain. Vol. 15. Advances in pain research and therapy. New York: Raven Press, Ltd. 1990:p. 209-214.
Schlegel SI. General characteristics of nonsteroidal anti-inflammatory drugs. In: Paulus HE, Furst DE, Dromgoole SH, editors. Anti-inflammatory agents, non-steroidal. Vol. 16. Drugs for rheumatic disease. New York: Churchill Livingstone. 1987:p. 203-26.
Schofferman J, Brody R. Pain in far advanced AIDS. In: Foley KM, Bonica JJ, Ventafridda V, editors. Proceedings of the Second International Congress on Cancer Pain. Vol. 16. Advances in pain research and therapy. New York: Raven Press, Ltd. 1990:p. 379-86.
Schug SA, Zech D, Dorr U. Cancer pain management according to WHO analgesic guidelines. J Pain Symptom Manage. 1990;5(1):27-32. [pmid: 2324558].
Schvarcz JR. Spinal cord stereotactic techniques re: trigeminal nucleotomy and extralemniscal myelotomy. Appl Neurophysiol. 1978;41(1-4):99-112. [pmid: 365105].
Sear JW, Hand CW, Moore RA, McQuay HJ. Studies on morphine disposition: influence of renal failure on the kinetics of morphine and its metabolites. Br J Anaesth. 1989;62(1):28-32. [pmid: 2644963].
Shapiro RS. Legal bases for control of analgesic drugs. J Pain Symptom Manage in press.
Shapiro RS. Liability issues in the management of pain. J Pain Symptom Manage in press.
Sherry MM, Greco FA, Johnson DH, Hainsworth JD. Breast cancer with skeletal metastases at initial diagnosis. Distinctive clinical characteristics and favorable prognosis. Cancer. 1986a;58(1):178-82. [pmid: 2423224].
Sherry MM, Greco FA, Johnson DH, Hainsworth JD. Metastatic breast cancer confined to the skeletal system. An indolent disease. Am J Med. 1986b;81(3):381-6. [pmid: 2428242].
Siegel LJ, Peterson L. Maintenance effects of coping skills and sensory information on young children's response to repeated dental procedures. Behav Ther. 1981;12(4):530-5.
Sievers TD, Yee JD, Foley ME, Blanding PJ, Berde CB. Midazolam for conscious sedation during pediatric oncology procedures: safety and recovery parameters. Pediatrics. 1991;88(6):1172-9. [pmid: 1956734].
Silberstein EB. Review of efficacy of strontium 89 therapy. Unpublished manuscript.
Silberstein EB, Elgazzar AH, Kapilivsky A. Phosphorus-32 radiopharmaceuticals for the treatment of painful osseous metastases. Semin Nucl Med. 1992;22(1):17-27. [pmid: 1589802].
Silberstein EB, Williams C. Strontium-89 therapy for the pain of osseous metastases. J Nucl Med. 1985;26(4):345-8. [pmid: 3920361].
Sindou M, Fischer G, Goutelle A, Allegre GE. Micro surgical selective posterior rhizotomy. 69 cases. Pain 1981. 1981;(suppl. 1).
Singer EJ, Zorilla C, Fahy-Chandon B, Chi S, Syndulko K, Tourtellotte WW. Painful symptoms reported by ambulatory HIV-infected men in a longitudinal study. Pain. 1993;54(1):15-9. [pmid: 8378098].
Siscovick DS, LaPorte RE, Newman JM. The disease-specific benefits and risks of physical activity and exercise. Public Health Rep. 1985;100:180-8. [pmid: 3920716]. [pmcid: 1424738].
Sjolund BH, Eriksson MBE. Endorphins and analgesia produced by peripheral conditioning stimulation. In: Bonica JJ, Liebeskind DG, Albe-Fessard D, editors. Proceedings of the Second World Congress on Pain, Montreal, Quebec. 1979;Vol. 3:p. 587-92.
Smith JA. Palliation of painful bone metastases from prostate cancer using sodium etidronate. J Urol. 1989;141:results of a randomized, prospective, double-blind, placebo-controlled study. 85. 87.
Sorkin BA, Rudy TE, Hanlon RB, Turk DC, Stieg RL. Chronic pain in old and young patients: differences appear less important than similarities. J Gerontol. 1990;45(2):P64-8. [pmid: 2313050].
Spiegel D, Bloom JR. Group therapy and hypnosis reduce metastatic breast carcinoma pain. Psychosom Med. 1983;45(4):333-9. [pmid: 6622622].
Spiegel D, Bloom JR, Kraemer HC, Gottheil E. Effect of psychosocial treatment on survival of patients with metastatic breast cancer. Lancet. 1989;2(8668):888-91. [pmid: 2571815].
Spiegel K, Kalb R, Pasternak GW. Analgesic activity of tricyclic antidepressants. Ann Neurol. 1983;13(4):462-5. [pmid: 6838179].
Spross JA. The CNS as collaborator. In: Hamric AB, Spross JA, editors. The clinical nurse specialist in theory and practice. 2nd ed. Philadelphia: WB Saunders Co. 1989:p. 205-26.
Spross JA, McGuire DB, Schmitt RM. Oncology Nursing Society Position Paper on Cancer Pain. Part I: introduction and background. Oncol Nurs Forum. 1990a;17(4):595-614. [pmid: 2399169].
Spross JA, McGuire DB, Schmitt RM. Oncology Nursing Society Position Paper on Cancer Pain. Part II: education. Oncol Nurs Forum. 1990b;17(5):751-60. [pmid: 2251194].
Spross JA, McGuire DB, Schmitt RM. Oncology Nursing Society Position Paper on Cancer Pain. Part III: nursing administration. Oncol Nurs Forum. 1990c;17(6):944-5. [pmid: 2263520].
Sriwatanakul K, Kelvie W, Lasagna L. The quantification of pain: an analysis of words used to describe pain and analgesia in clinical trials. Clin Pharmacol Ther. 1982;32(2):143-8. [pmid: 7094502].
Stein C. Peripheral mechanisms of opioid analgesia. Anesth Analg. 1993;76(1):182-91. [pmid: 8380316].
Stiefel F, Holland J. Delirium in cancer patients. International Psychogeriatrics. 1991;3(2):222-6.
Stiefel FC, Breitbart WS, Holland JC. Corticosteroids in cancer: neuropsychiatric complications. Cancer Invest. 1989;7(5):479-91. [pmid: 2695230].
Stjernsward J, Teoh N. The scope of the cancer pain problem. In: Foley KM, Bonica JJ, Ventafridda V, editors. Proceedings of the Second International Congress on Cancer Pain. 1990. 1988; Rye, NY;Vol. 16. Advances in pain research and therapy. New York: Raven Press, Ltd.:p. 7-12.
Stover J. Cancer pain: A patient's view. Unpublished manuscript February. 1992.
Stuart JJ, Pisko EJ. Choline magnesium trisalicylate does not impair platelet aggregation. Pharmatherapeutica. 1981;2(8):547-51. [pmid: 7255512].
Stuart MJ, Murphy S, Oski FA, Evans AE, Donaldson MH, Gardner FH. Platelet function in recipients of platelets from donors ingesting aspirin. N Engl J Med. 1972;287(22):1105-9. [pmid: 5082189].
Sunshine A, Olson NZ. Non-narcotic analgesics. In: Wall PD, Melzack R, editors. Textbook of Pain. 2nd Ed. New York: Churchill Livingstone. 1989:p. 670-85.
Sutor AH, Bowie EJ, Owen CA Jr. Effect of aspirin, sodium salicylate, and acetaminophen on bleeding. Mayo Clin Proc. 1971;46(3):178-81. [pmid: 5553128].
Swanson G, Smith J, Bulich R, New P, Shiffman R. Patient-controlled analgesia for chronic cancer pain in the ambulatory setting: a report of 117 patients. J Clin Oncol. 1989;7(12):1903-8. [pmid: 2479720].
Sweet WH. Treatment of facial pain by percutaneous differential thermal trigeminal rhizotomy. Prog Neurol Surg. 1976;7:153-79.
Swerdlow M. Anticonvulsant drugs and chronic pain. Clin Neuropharmacol. 1984;7(1):51-82. [pmid: 6367974].
Swerdlow M. Role of chemical neurolysis and local anesthetic infiltration. In: Swerdlow M, Ventafridda V, editors. Cancer pain. Lancaster: MTP Press. 1987.
Syrjala KL. Integrating medical and psychological treatments for cancer pain. In: Chapman CR, Foley KM, editors. Current and emerging issues in cancer pain: research and practice. New York: Raven Press, Ltd. in press.
Syrjala KL. Relaxation techniques. In: Bonica JJ, editor. The management of pain. 2nd ed. Vol. II. Philadelphia: Lea & Febiger. 1990:p. 1742-50.
Syrjala KL, Cummings C, Donaldson GW. Hypnosis or cognitive behavioral training for the reduction of pain and nausea during cancer treatment: a controlled clinical trial. Pain. 1992;48(2):137-46. [pmid: 1350338].
Szeto HH, Inturrisi CE, Houde R, Saal S, Cheigh J, Reidenberg MM. Accumulation of normeperidine, an active metabolite of meperidine, in patients with renal failure of cancer. Ann Intern Med. 1977;86(6):738-41. [pmid: 869353].
Takeda F. Results of field-testing in Japan of the WHO draft interim guidelines on relief of cancer pain. Pain Clin. 1986;1:83-9.
Takeda F, Fujii T, Uki J, Fuse Y, Tozawa R, Kitani Y, Fujita T. Cancer pain relief and tumor regression by means of pituitary neuroadenolysis and surgical hypophysectomy. Neurol Med Chir (Tokyo). 1983;23(1):41-9. [pmid: 6188981].
Tasker RR. Percutaneous cordotomy: the lateral high cervical technique. In: Schmidek HH, Sweet WH, editors. Operative neurosurgical techniques: indications, methods, and results. 2nd ed. Vol. 2. Philadelphia: WB Saunders Co. 1988:p. 1191-205.
Teamwork:. Silver Spring, MD: National Coalition for Cancer Survivorship. 1991.
Tejwani GA, Rattan AK, McDonald JS. Role of spinal opioid receptors in the antinociceptive interactions between intrathecal morphine and bupivacaine. Anesth Analg. 1992;74:726-34. [pmid: 1314527].
Tennant FS Jr, Uelmen GF. Prescribing narcotics to habitual and addicted narcotics users. Medical and legal guidelines in California and some other Western states. West J Med. 1980;133(6):539-45. [pmid: 7467311].
Teoh N, Stjernsward J. WHO cancer pain relief program—ten years on. Seattle: International Association for the Study of Pain, IASP Newsletter. 1992:p.5-6.
ter Riet G, Kleijnen J, Knipschild P. Acupuncture and chronic pain: a criteria-based meta-analysis. J Clin Epidemiol. 1990;43(11):1191-9. [pmid: 2147032].
Tesler MD, Savedra MC, Holzemer WL, Wilkie DJ, Ward JA, Paul SM. The word-graphic rating scale as a measure of children's and adolescents' pain intensity. Res Nurs Health. 1991;14(5):361-71. [pmid: 1891622].
Thames HD, Withers HR, Peters LJ, Fletcher GH. Changes in early and late radiation responses with altered dose fractionation: implications for dose-survival relationships. Int J Rad Biol Phys. 1982;8:219-26.
Thangathurai D, Bowles HF, Allen HW, Mikhail M. The incidence of pruritus after epidural morphine (letter). Anaesthesia. 1988;43(12):1055-6. [pmid: 3232785].
Tobias JD. Pediatric pain management: the use of non-narcotic analgesic agents. Analgesia: J Pain Ther Health Care Prof. 1992;3(3):4-6.
Todd KH, Samaroo N, Hoffman JR. Ethnicity as a risk factor for inadequate emergency department analgesia. JAMA. 1993;269(12):1537-9. [pmid: 8445817].
Tong D, Gillick L, Hendrickson FR. The palliation of symptomatic osseous metastases: final results of the Study by the Radiation Therapy Oncology Group. Cancer. 1982;50(5):893-9. [pmid: 6178497].
Turkington RM. Depression masquerading as diabetic neuropathy. JAMA. 1980;243:1147-50. [pmid: 6987418].
Turner JH, Claringbold PG, Hetherington EL, Sorby P, Martindale AA. A phase I study of samarium-153 ethylenediaminetetramethylene phosphonate therapy for disseminated skeletal metastases. J Clin Oncol. 1989;7(12):1926-31. [pmid: 2585026].
Twycross RG. Choice of strong analgesic in terminal cancer: diamorphine or morphine?. Pain. 1977;3:93-104. [pmid: 69290].
Uniform Controlled Substances Act (1990), U. L.A. Vol. 9, Part II sec 101 et seq.
US Department of Health and Human Services, Agency for Health Care Policy and Research. Public Meeting on Clinical Practice Guidelines for Cancer-Related Pain. Federal Register July 31. 1991;Vol. 56(147):36155-36156, and Federal Register Aug 20. 1991. Vol. 56(161).
van Dongen RT, Crul BJ. Paraplegia following coeliac plexus block. Anaesthesia. 1991;46(10):862-3. [pmid: 1952003].
van Holten-Verzantvoort ATM, Zwinderman AH, Aaronson NK, Hermans J, van Emmerik B, van Dam FS, van den Bos B, Bijvoet OL, Cleton FJ. The effect of supportive pamidronate treatment on aspects of quality of life of patients with advanced breast cancer. Eur J Cancer. 1991;27:544-549. [pmid: 1675865].
van Roost D, Gybels J. Myelotomies for chronic pain. Acta Neurochir Suppl (Wien). 1989;46:69-72. [pmid: 2672715].
Varvel JR, Shafer SL, Hwang SS, Coen PA, Stanski DR. Absorption characteristics of transdermally administered fentanyl. Anesthesiology. 1989;70(6):928-34. [pmid: 2729633].
Vasudevan S, Hegmann K, Moore A, Cerletty S. Physical methods of pain management. In: Raj PP, editor. Practical management of pain. 2nd ed. Baltimore: Mosby Year Book Medical Publishers. 1992:p. 669-79.
Ventafridda V, Bianchi M, Ripamonti C, Sacerdote P, De Conno F, Zecca E, Panerai AE. Studies on the effects of antidepressant drugs on the antinociceptive action of morphine and on plasma morphine in rat and man. Pain. 1990;43(2):155-62. [pmid: 2087328].
Ventafridda V, Bonezzi C, Caraceni A, De Conno F, Guarise G, Ramella G, Saita L, Silvani V, Tamburini M, Toscani F. Antidepressants for cancer pain and other painful syndromes with deafferentation component: comparison of amitriptyline and trazodone. Ital. J Neurol Sci. 1987;8(6):579-87. [pmid: 3323130].
Ventafridda V, Caraceni A, Gamba A. Field-testing of the WHO Guidelines for Cancer Pain Relief: summary report of demonstration projects. In: Foley KM, Bonica JJ, Ventafridda V, editors. Proceedings of the Second International Congress on Pain. 1990;Vol. 16. Advances in pain research and therapy. New York: Raven Press, Ltd:p. 451-64.
Ventafridda GV, Caraceni AT, Sbanotto AM, Barletta L, De Conno F. Pain treatment in cancer of the pancreas. Eur J Surg Oncol. 1990;16:1-6. [pmid: 1689676].
Verrill PJ. Adverse effects and complications of stellate lumbar and splanchnic sympathetic blocks with neurolytic preparations. In: Mumenthaler M, Van Zwieten PA, Farcot JM, editors. Treatment of chronic pain: possibilities, limitations and long-term follow-up. New York: Harwood Academic Publishers. 1990:p. 127-33.
Von Roenn JH, Cleeland CS, Gonin R, Hatfield AK, Pandya KJ. Physician attitudes and practice in cancer pain management. Ann Intern Med. 1993;119(2). 121. 6. [pmid: 8099769].
Wagner G. Frequency of pain in patients with cancer. Recent Results Cancer Res. 1984;89:64-71. [pmid: 6364273].
Waldman SD. Acute herpes zoster involving the chest wall. In: Ferrer-Brechner T. Common problems in pain management. Littleton, Mass: Year Book Medical Publishers, Inc. 1990:p. 143-51.
Walker KN, MacBride A, Vachon ML. Social support networks and the crisis of bereavement. Soc Sci Med. 1977;11(1):35-41. [pmid: 887956].
Walker VA, Hoskin PJ, Hanks GW, White ID. Evaluation of WHO Analgesic Guidelines for Cancer Pain in a hospital-based palliative care unit. J Pain Symptom Manage. 1988;3(3):145-9. [pmid: 2458415].
Wallston K, Wallston B, Smith S, et al. Perceived control and health. Current Psychological Research and Reviews. 1987;6(1):5-25.
Walsh TD. Oral morphine in chronic cancer pain. Pain. 1984;18:1-11. [pmid: 6200818].
Wang BC, Hillman DE, Spielholz NI, Turndorf H. Chronic neurological deficits and nesacaine-CE: an effect of the anesthetic, 2-chloroprocaine, or the antioxidant, sodium bisulfite?. Anesth Analg. 1984;63:445-7. [pmid: 6703372].
Ward SE, Goldberg N, Miller-McCauley V, Mueller C, Nolan A, Pawlik-Plank D, Robbins A, Stormoen D, Weissman DE. Patient-related barriers to management of cancer pain. Pain. 1993;52(3):319-24. [pmid: 7681557].
Watson CP, Evans RJ. A comparative trial of amitriptyline and zimelidine in post-herpetic neuralgia. Pain. 1985;23(4):387-94. [pmid: 2935772].
Watson CP, Evans RJ, Reed K, Merskey H, Goldsmith L, Warsh J. Amitriptyline versus placebo in postherpetic neuralgia. Neurology. 1982;32:671-3. [pmid: 6283422].
Weekes DP, Savedra MC. Adolescent cancer: coping with treatment-related pain. J Pediatr Nurs. 1988;3(5):318-28. [pmid: 3171896].
Weingart WA, Sorkness CA, Earhart RH. Analgesia with oral narcotics and added ibuprofen in cancer patients. Clin Pharm. 1985;4(1):53-8. [pmid: 3971683].
Weiss HJ, Aledort LM, Kochwa S. The effect of salicylates on the hemostatic properties of platelets in man. J Clin Invest. 1968;47(9):2169-80. [pmid: 5675432].
Weissman DE. Glucocorticoid treatment for brain metastases and epidural spinal cord compression: a review. J Clin Oncol. 1988;6:543-51. [pmid: 3280744].
Weissman DE, Burchman SL, Dinndorf PA, Dahl JL. Handbook of cancer pain management. 2nd ed. Madison, WI: Wisconsin Cancer Pain Initiative. 1988 [updated 1990, 1992].
Weissman DE, Burchman SL, Dinndorf PA, Dahl JL. Handbook of cancer pain management. 3rd ed. Madison, WI: Wisconsin Cancer Pain Initiative. 1992;:p.7-8.
Weissman DE, Haddox JD. Opioid pseudoaddiction—an iatrogenic syndrome. Pain. 1989;36(3):363-6. [pmid: 2710565].
Weissman DE, Joranson DE, Hopwood MB. Wisconsin physicians' knowledge and attitudes about opioid analgesic regulations. Wis Med J. 1991;90(12):671-5. [pmid: 1688197].
Wells DG, Bjorksten AR. Monoamine oxidase inhibitors revisited. Can J Anaesth. 1989;36(1):67-74.
White JC, Sweet WH. Pain and the neurosurgeon. A forty-year experience. Springfield: Thomas Press. 1969.
Whitney SL. Physical agents: heat and cold modalities. In: Scully R, Barnes M, editors. Physical therapy. Philadelphia: JB Lippincott Co. 1989:p. 844-75.
Wilkie D, Lovejoy N, Dodd M, Tesler M. Cancer pain control behaviors: description and correlation with pain intensity. Oncol Nurs Forum. 1988;15(6):723-31. [pmid: 3205831].
Wilner D. Radiology of bone tumors and allied disorders. In: Wilner DM, editor. Cancer metastasis to bone. Philadelphia: WB Saunders. 1982:p. 3641-908.
Wilson JF. Behavioral preparation for surgery: benefit or harm?. J Behav Med. 1981;4(1):79-102. [pmid: 7026795].
Wisconsin Cancer Pain Initiative. Cancer pain can be relieved: a guide for patients and families. Madison, WI: Wisconsin Cancer Pain Initiative. 1988.
Wisconsin Cancer Pain Initiative. Children's cancer pain can be relieved. Madison, WI: Wisconsin Cancer Pain Initiative. 1989.
Wisconsin Cancer Pain Initiative. Jeff asks about cancer pain. Madison, WI: Wisconsin Cancer Pain Initiative. 1990.
World Health Organization. Cancer pain relief and palliative care. Report of a WHO expert committee [World Health Organization Technical Report Series, 804] . Geneva, Switzerland: World Health Organization. 1990:p. 1-75.
Yajnik S, Singh GP, Singh G, Kumar M. Phenytoin as a coanalgesic in cancer pain. J Pain Symptom Manage. 1992;7:209-13. [pmid: 1517643].
Yaksh TL, Rudy TA. Analgesia mediated by a direct spinal action of narcotics. Science. 1976;192(4246):1357-8. [pmid: 1273597].
Yanagida H, Suwa K, Trouwborst A, Erdmann W, et al. Electrical stimulation of the pituitary—its use in the treatment of cancer pain. Pain Clinic. 1988;2(4):225-8.
Yasco JM, Verfurth M. Closing comment: economic trends. Semin Oncol Nurs. 1992;8(2):156-8.
Young RF, Brechner T. Electrical stimulation of the brain for relief of intractable pain due to cancer. Cancer. 1986;57(6):1266-72. [pmid: 3484665].
Young RJ, Clarke BF. Pain relief in diabetic neuropathy: the effectiveness of imipramine and related drugs. Diabetic Med. 1985;2(5):363-6. [pmid: 2435449].
Zeltzer LK, Altman A, Cohen D, LeBaron S, Maunuksela EL, Schechter NL. American Academy of Pediatrics Report of the Subcommittee on the Management of Pain Associated with Procedures in Children with Cancer. Pediatrics. 1990;86(5):826-31. [pmid: 2216645].
Zeltzer LK, Jay SM, Fisher DM. The management of pain associated with pediatric procedures. Pediatr Clin North Am. 1989;36(4):941-64. [pmid: 2569184].
Zeltzer L, LeBaron S. Hypnosis and nonhypnotic techniques for reduction of pain and anxiety during painful procedures in children and adolescents with cancer. J Pediatr. 1982;101(6):1032-5. [pmid: 7143158].
Zucker MB, Rothwell KG. Differential influences of salicylate compounds on platelet aggregation and serotonin release. Curr Ther Res. 1978;Feb 23(2):194-9.