# Explanation of Strength of Evidence

This guideline contains recommendations at the beginning of each chapter. Recommendations are followed in parentheses by a rating of the strength of evidence.

When the strength of evidence is A or B, the panel's recommendations are based primarily on the evidence. When the strength of recommendation is C or D, the panel used the available empirical evidence but based their recommendations primarily on expert judgment. When the recommendation is a statement of panel opinion regarding desirable practice and there is evidence that the practice is not commonly being followed, the term "panel consensus" is used.

A more complete explanation of strength of evidence is contained in Attachment A.