# Acknowledgments

The Cancer Pain Management Panel expresses profound appreciation to the patients who helped us in the development of the consumer version of the guideline and to our numerous colleagues in many disciplines who made valuable contributions during the development of the guideline. The scientific reviewers critiqued sections or complete drafts of the guideline document, and a variety of individuals pilot tested the guideline. A full listing of those involved in this effort appears in the list of contributors at the end of the document. Special recognition goes to Ehud Arbit, MD, Andrew Brown, MB BS, Stuart DuPen, MD, Nora Janjan, MD, Mathew Lefkowitz, MD, Margo McCaffery, RN, MS, Raphael Pollock, MD, PhD, Karen Syjala, PhD, Anna Williams, RN, MN, and Melissa Wolff, RT, MS all of whom provided original text for the document. We also acknowledge the extraordinary review efforts of Charles Cote MD, June Dahl, PhD, Stuart Grossman, MD, Philipp Lippe, MD, Margo McCaffery, RN, MS, Patricia McGrath, PhD, Richard Patt, MD, Vivian Sheidler, RN, MS, Thomas Smith, MD, and Sridhar Vasudevan, MD. These individuals provided major and repeated reviews of various aspects of the guideline, as well as valuable advice to the panel chairs.

We acknowledge the critical approach and tireless, energetic efforts to the many aspects of guideline development of Jane Ballantyne, MB, Elon Eisenberg, MD, Donna Mahrenholz, RN, PhD, and particularly Janice Ulmer, RN, PhD, all of whom served as staff to the panel. Dr. Patricia Stephens provided excellent and timely editing for several drafts of the guideline. Research assistants who provided valuable services in reviewing the literature included Dorothy Herron, RN, MSN, Yeonghee Shin, RN, PhD, and Joyce Willens, RN, MSN. Other valuable services in the preparation of various materials were provided by research assistants Leslie Dunham, Stella Seal, Sabreena Woods, and our secretary, Yvonne Deane-Hibbert, at the Johns Hopkins University. Drs. Frederick Mosteller, Thomas Chalmers, and Catherine Berkey of the Technology Assessment Group, Harvard School of Public Health, gave valuable guidance during literature reviews for meta-analyses. Miss Evelyn Hall, at Massachusetts General Hospital, provided expert secretarial assistance in the development of guideline materials. Drs. Richard Kitz and George Battit of the Massachusetts General Hospital provided ongoing support and encouragement for work at that site.