# Panel Members

- Ada Jacox, RN, PhD, FAAN, (1991-94) Co-Chair
- Independence Foundation Chair in Health Policy School of Nursing>
- The Johns Hopkins University
- Baltimore, Maryland
- Specialties: Health Policy, Outcomes Research

- Daniel B. Carr, MD, Co-Chair, (1991-92)
- Special Consultant (1992-94) Director, Division of Pain Management Department of Anesthesia
- Massachusetts General Hospital
- Boston, Massachusetts
- Specialties: Anesthesiology, Endocrinology

- Richard Payne, MD, Member (1991-94) Co-Chair (1992-94)
- Director, Pain and Symptom Management Section
- MD Anderson Cancer Center
- Houston, Texas
- Specialties: Neurology, Oncology

- Charles B. Berde, MD, PhD (1992-94)
- Director, Pain Treatment Service
- Children's Hospital
- Boston, Massachusetts
- Specialties: Pediatrics, Anesthesia, Critical Care

- William Breitbart, MD (1991-94)
- Associate Member
- Memorial Sloan-Kettering Cancer Center
- New York, New York
- Specialty: Psychiatry, Internal Medicine

- Joanna M. Cain, MD (1992-94)
- Director, Women's Clinic
- Division of Gynecologic Oncology
- University of Washington Hospital
- Seattle, Washington
- Specialties: Obstetrics, Gynecologic Oncology

- C. Richard Chapman, PhD (1991-92)
- Professor, Department of Anesthesiology
- University of Washington School of Medicine
- Director, Pain and Toxicity Research Program
- Fred Hutchinson Cancer Research Center
- Seattle, Washington
- Specialty: Psychology

- Charles S. Cleeland, PhD (1992-94)
- Director, Pain Research Group
- Professor, Neurology
- Department of Neurology
- University of Wisconsin Medical School
- Madison, Wisconsin
- Specialty: Psychology

- Betty R. Ferrell, RN, PhD, FAAN (1991-94)
- Associate Research Scientist, Nursing Research
- City of Hope Medical Center
- Duarte, California
- Spealties: Oncology, Nursing

- Rebecca S. Finley, PharmD, MS (1992-94)
- Head, Section of Pharmacy Services
- University of Maryland Cancer Center
- Associate Professor of Oncology
- Associate Professor of Pharmacy Practice
- University of Maryland School of Pharmacy
- Baltimore, Maryland
- Specialty: Institutional Pharmacy

- Nancy O. Hester, RN, PhD, FAAN (1991-94)
- Associate Professor, School of Nursing
- University of Colorado Health Sciences Center
- Denver, Colorado
- Specialties: Pediatrics, Research Methods

- C. Stratton Hill, Jr., MD (1991-92)
- Professor of Medicine
- University of Texas MD Anderson Cancer Center
- Houston, Texas
- Specialty: Oncology

- W. David Leak, MD, FACPM (1992-94)
- Medical Director, Pain Control Consultants
- Adjunct Staff,
- Cleveland Clinic Foundation
- Westerville, Ohio
- Specialty: Pain Medicine

- Arthur G. Lipman, PharmD (1991-92)
- Professor of Clinical Pharmacy
- College of Pharmacy
- University of Utah
- Salt Lake City, Utah
- Specialty: Pharmacology in Pain Symptom Control

- Catherine L. Logan (1992-94)
- Executive Director and Founder, Living Through Cancer, Inc.
- Board of Advisors,
- National Coalition for Cancer Survivorship
- Albuquerque, New Mexico
- Consumer Representative

- Charles L. McGarvey, PT, MS (1991-92)
- Chief, Physical Therapy Section
- Rehabilitation Medicine Department
- Warren G. Magnuson Clinical Center
- National Institutes of Health
- Bethesda, Maryland
- Specialty: Physical Therapy

- Christine A. Miaskowski, RN, PhD, FAAN (1991-92)
- Associate Professor, Department of Physiological Nursing
- University of California, San Francisco
- San Francisco, California
- Specialty: Oncology

- David Stevenson Mulder, MD (1991-92)
- Professor of Surgery, McGill University
- Surgeon-in-Chief,
- Montreal General Hospital
- Montreal, Quebec, Canada
- Specialty: Cardiothoracic Surgery

- Judith A. Paice, RN, PhD (1992-94)
- Clinical Specialist, Pain Management
- Neuroscience Institute
- Rush-Presbyterian-St. Luke's Medical Center
- Chicago, Illinois
- Specialty: Neurosurgery, Oncology

- Barbara S. Shapiro, MD (1991-92)
- Associate Director, Pain Management Program
- Children's Hospital of Philadelphia
- Assistant Professor of Pediatrics
- University of Pennsylvania School of Medicine
- Philadelphia, Pennsylvania
- Specialties: General Pediatrics, Pain Management

- Edward B. Silberstein, MD, FACNP (1992-94)
- Associate Director, E. L. Saenger Radioisotope Laboratory
- University of Cincinnati Medical Center
- Professor of Medicine and Radiology
- University of Cincinnati College of Medicine
- Cincinnati, Ohio
- Specialties: Nuclear Medicine, Internal Medicine, Hematology, Oncology

- Rev. Robert S. Smith, PhD (1991-92)
- Director, Institute for Medicine in Contemporary Society
- State University Medical Center at Stony Brook
- Stony Brook, New York
- Specialty: Religion, Ethics

- Jeanne Stover (1991-92)
- Cofounder of Living Through Cancer, Inc.
- Sandia Park, New Mexico
- Consumer Representative

- Carole V. Tsou, MD (1991-92)
- Residency Program Director
- University of Hawaii
- Department of Family Practice
- Mililani, Hawaii
- Specialty: Family Medicine

- Loretta Vecchiarelli ( 1991-92)
- Rehabilitation Hospital of Western New England
- Ludlow, Massachusetts
- Consumer Representative

- David E. Weissman, MD (1992-94)
- Associate Professor of Medicine
- Division of Cancer and Blood Diseases
- Medical College of Wisconsin
- Milwaukee, Wisconsin
- Specialties: Internal Medicine, Oncology