# Dedication

TheClinical Practice Guideline for the Management of Cancer Pain is dedicated to the memory of Jeanne Stover, a member of the panel that developed the guidelines. Jeanne represented the National Coalition for Cancer Survivorship on the panel. A 23-year survivor of breast cancer, she had metastatic disease during the last 9 years of her life and succumbed to this disease during her tenure as a panel member. She was a founding member of Living Through Cancer, a cancer self-help group in Albuquerque, New Mexico. The panel appreciates the insights and wisdom that Jeanne shared with us.