# Contributors

## Benign Prostatic Hyperplasia Guideline Panel

- John D. McConnell, MD, Chair
- Chairman, Division of Urology
- Department of Surgery
- Southwestern Medical Center
- University of Texas
- Dallas, Texas

Dr. McConnell is Director and Principal Investigator of the George W. O'Brien Urology Research Center (funded by the National Institutes of Health), which focuses on regulation of benign and malignant prostate growth. Dr. McConnell has published extensively on the clinical and basic science of BPH and has participated in clinical trials with both medical and new invasive BPH treatments. He is Vice-Chairman of the Steering Committee of a recently NIDDK-funded trial focusing on BPH progression. He is Chairman of the Hormonal Therapy Committee of the International Consensus meeting on BPH sponsored by the World Health Organization. Dr. McConnell is Vice-Chairman of the AUA's Practice Parameters, Guidelines, and Standards Committee. The AUA recognized his work in 1991 with its Gold Cystoscope Award, given for the most outstanding contributions to urology within 10 years of residency training.

- Michael J. Barry, MD
- Assistant Professor of Medicine
- Harvard Medical School
- Cambridge, Massachusetts
- Massachusetts General Hospital
- Boston, Massachusetts

Dr. Barry is Director of the Health Services Research Program in the Medical Practices Evaluation Center and a practicing internist in the General Internal Medicine Unit at Massachusetts General Hospital. He is a member of the AHCPR-funded Patient Outcomes Research Team (PORT) for BPH and localized prostate cancer as well as of the Prostate Health Council of the American Foundation for Urologic Diseases. His research involves health status measurement in BPH, defining the outcomes of care for prostatic diseases, and the involvement of patients in medical decisionmaking.

- Reginald C. Bruskewitz, MD
- Professor of Surgery
- University Hospital and Clinics
- University of Wisconsin-Madison
- Madison, Wisconsin

Dr. Bruskewitz is Professor of Surgery, University of Wisconsin Hospital and Clinics. He was a resident in urology at University Hospital in 1974-78; a Fellow at the University of California, Los Angeles, in 1978-79; and President of the Wisconsin Urological Society in 1988. Dr. Bruskewitz has published widely in the field of urology and is author or coauthor of numerous scientific papers.

- Anton J. Bueschen, MD
- Professor and Director
- Division of Urology/Department of Surgery
- University of Alabama at Birmingham School of Medicine
- Birmingham, Alabama

Dr. Bueschen received his MD from the University of Virginia. He received residency training in surgery at Vanderbilt University and completed his residency in urology at Indiana University Medical Center. He was a member of the faculty of the School of Medicine at Tulane University in 1972 and 1973. He joined the faculty of the School of Medicine at the University of Alabama at Birmingham in 1973 and has been the Director of the Division of Urology since 1975. While being very active in the clinical practice of urology, he has also been involved in the education of medical students, residents, and urologists. He is a Fellow of the American College of Surgeons and a member of the American Urologic Association (AUA) and the Society of Urologic Oncology.

- Sherwood E. Denton, MD
- Phoenix, Arizona

Sherwood Edwin Denton, MD, was graduated with distinction from the University of Michigan Medical School in 1958. Dr. Denton received his urologic training at the University of Kansas in Kansas City before moving to Phoenix to join Urology Associates, Limited. Until retirement in 1990, he was in private practice. Dr. Denton's involvement in developing the BPH clinical practice guideline became a mission and purpose for living in the last months of life. He died on June 1, 1992.

Dr. Denton was a consummate patient advocate whether dealing with insurance plans or hospitals or as a physician. He was a local pioneer in urology. He helped to establish the Phoenix organ transplant program and was co-surgeon in the first kidney transplant in Phoenix. He was instrumental in establishing the first extracorporeal shock wave lithotripsy center in Phoenix, which was the first stone center of its kind in the Southwest. He served on the staff and Board of Directors of St Joseph's Hospital for many years.

- H. Logan Holtgrewe, MD, FACS
- Assistant Professor of Urology
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

Dr. Holtgrewe is immediate Past President of the AUA and a clinical urologist practicing in Annapolis, Maryland. He has had a career-long interest in BPH, has numerous publications in the medical literature dealing with it, and chaired the Committee on the Economic Aspects of Benign Prostatic Hyperplasia during the 1991 and 1993 Consultations on Benign Prostatic Hyperplasia sponsored by the World Health Organization in Paris, France. He has had an extensive involvement in the development of guidelines for urological diseases undertaken by the AUA and is a coprincipal investigator for the AUA's ongoing clinical outcomes trial in the treatment of BPH. He is a member of the Urology Program Advisory Group to the National Institute of Diabetes and Digestive and Kidney Diseases of the National Institutes of Health (NIH) and a member of the National Kidney and Urological Disease Information Clearinghouse, NIH.

- John L. Lange, MD
- Holt-Krock Clinic
- Fort Smith, Arkansas

Dr. Lange received his MD from the University of Oklahoma in 1975 and completed his residency training in urology at the University of Texas Medical Center in 1984. He is now in private practice at the Holt-Krock Clinic in Fort Smith, Arkansas. The Holt-Krock Clinic is a 150-doctor multispecialty clinic, a fully integrated health care system with a large primary care network, outpatient dialysis, radiation oncology, and ambulatory surgery center. Dr. Lange currently serves as Vice President in Charge of Medical Affairs and is responsible for quality improvement, continuing education, recruitment, medical information, and risk management. He also has an appointment as a clinical Assistant Professor in urology associated with the University of Arkansas Medical Center and, in this role, is involved in training family practice residents. He is a member of the AUA, a diplomat of the American Board of Urology, and a member of the Societe Internationale d'Urologie.

- Bruce L. McClennan, MD, FACR
- Professor of Radiology
- Director, Abdominal Imaging Section
- Mallinckrodt Institute of Radiology
- Washington University School of Medicine
- St. Louis, Missouri

Dr. McClennan is Professor of Radiology and Director of the Abdominal Imaging Section at Mallinckrodt Institute of Radiology in St. Louis, Missouri. Dr. McClennan is a Fellow of the American College of Radiology (ACR) and serves on its Board of Chancellors. He is also Chairman of the ACR Committee on Drugs and Contrast Media and Chairman of the ACR Intersociety Commission. Dr. McClennan serves as a consultant to the FDA Center for Drug Evaluation and Research and is past President of the Society of Uroradiology. A genitourinary radiologist, Dr. McClennan is author or coauthor of over 100 scientific papers as well as numerous textbook chapters. He is widely regarded as an expert on the topic of contrast media and genitourinary computed tomography.

- Winston K. Mebust, MD
- Professor and Chairman, Urology
- Kansas University Medical Center
- Kansas City, Kansas

Dr. Mebust is Professor and Chairman of Urology at the Kansas University Medical Center. He is the AUA's Chairman of the Committee on Practice Parameters, Guidelines, and Standards. He has written numerous papers on the surgical management of BPH, including indications for surgery, surgical technique, and postoperative care. He is an internationally recognized expert in the management of BPH. His current research is on the medical management of BPH and the use of lasers for treating BPH.

- Nancy J. Reilly, MSN, RN, CURN
- GI/GU Clinical Nurse Specialist
- University of Pennsylvania Medical Center
- Philadelphia, Pennsylvania

Ms. Reilly is a Certified Urology Nurse with extensive experience in the care of patients with urologic disorders. She maintains a special interest in prostate disease. She is a past President of the American Urological Association Allied (AUAA), an organization of over 2,500 urologic nurses and allied health professionals. Ms. Reilly is an appointed member of the Bladder Health Council, American Foundation for Urologic Disease. She was chairperson of the task force that created the Standards of Urologic Nursing Practice for AUAA. She has published numerous articles and chapters on issues related to the care of urologic patients and has lectured nationally on BPH, prostate cancer, genitourinary trauma, and other urologic diseases and disorders.

- Richard G. Roberts, MD, JD
- Professor Department of Family Medicine
- University of Wisconsin-Madison
- Madison, Wisconsin

Dr. Roberts is an Associate Professor in the Department of Family Medicine at the University of Wisconsin Medical School in Madison. A family physician and attorney, Dr. Roberts practices in Belleville, a rural community. He chairs the Task Force on Clinical Policies for Patient Care of the American Academy of Family Physicians. He serves on the Prostate Health Council, the Practice Parameters Partnership, and the Medical Advisory Panel of the Blue Cross and Blue Shield Association's Technology Evaluation Program. Dr. Roberts has also served on the World Health Organization's 1991 and 1993 International Consultations on Benign Prostatic Hyperplasia.

- Stephen A. Sacks, MD
- Associate Clinical Professor Surgery/Urology
- Center for the Health Sciences
- University of California at Los Angeles
- Los Angeles, California

Dr. Sacks is Associate Clinical Professor of Surgery/Urology at the UCLA Medical Center and has been Clinical Chief of Urology at the Cedars-Sinai Medical Center in Los Angeles. He has served as a member, task force chairman, editor, and consultant to the Examination Committee of the American Board of Urology. Dr. Sacks completed his undergraduate studies at UCLA and received his medical degree from the University of Southern California. Following service as Lieutenant Commander in the U.S. Navy Medical Corps, Dr. Sacks completed his residency in surgery and urology at the UCLA Medical Center. He is now engaged in the private practice of urology in Los Angeles.

- John H. Wasson, MD
- Herman O. West Professor of Geriatrics and Director for the Center for the Aging
- Dartmouth Medical School
- Hanover, New Hampshire

Dr. Wasson is Project Director of the Patient Outcomes Research Team for BPH and localized prostate cancer. While at the White River Veterans Affairs Medical Center, he was Coprincipal Investigator for the VA Cooperative Trial of Efficacy and Cost of Transurethral Resection for Symptomatic Benign Prostatic Hyperplasia.

## Consultants

- Research Analysis and Urology
- Claus G. Roehrborn, MD
- Assistant Professor of Surgery Division of Urology
- University of Texas Southwestern Medical Center

- Economics and Urology
- Peter G. Albertsen, MD, MS
- Assistant Professor of Surgery (Urology) Department of Urology
- University of Connecticut Health Center

- Urology
- Jerry G. Blaivas, MD
- Department of Urology
- College of Physicians and Surgeons
- New York, New York

- Methodology
- David M. Eddy, MD, PhD
- Professor of Health Policy and Management
- Duke University
- Senior Advisor for Health Policy and Management
- Kaiser Permanente, Southern California Region

- Statistical Analysis
- Victor Hasselblad, PhD
- Associate Research Professor
- Center for Health Policy Research and Education
- Duke University

- Prostate-Specific Antigen
- Joseph E. Oesterling, MD
- Associate Professor of Urology
- Mayo Clinic
- Rochester, Minnesota
- Editor-in-Chief, Urolog

- Health Care Economics
- Teh-Wei Hu, PhD
- Chairman, School of Public Health
- Department of Social and Administrative Health Sciences
- University of California at Berkeley

- Algorithm
- David C. Hadorn, MD, MA
- Professional Consultant
- RAND Corporation
- Santa Monica, California

## Peer Reviewers

- Peter Albertsen, MD, MS
- Assistant Professor
- University of Connecticut Health Center
- Farmington, Connecticut
- Steven Alexander, MD
- Clifton, New Jersey
- Rosemary Brekke, BSN, RN
- Reimbursement Analyst
- American Medical Systems
- Pfizer Hospital Products Group
- Minnetonka, Minnesota
- Joseph C. Cerny, MD
- Department of Urology
- Henry Ford Hospital
- Detroit, Michigan
- Clifton R. Cleaveland, MD
- Associates in Internal Medicine
- Chattanooga, Tennessee
- Roy J. Correa, Jr., MD
- Department of Surgery Virginia Mason Clinic
- Seattle, Washington
- Patricia A. Deverka, MD, MS
- Executive Director
- Outcomes Research
- Janssen Research Foundation
- Titusville, New Jersey
- Joseph Dowd, MD
- Urologist
- Needham, Massachusetts
- Judy Eastman
- American Medical Systems
- Minnetonka, Minnesota
- John W. Edwards, Jr., MD
- Urology Clinic, Inc.
- Honolulu, Hawaii
- Erdal Erturk, MD
- Department of Urology
- University of Rochester Medical Center
- Rochester, New York
- Thomas C. Fenter, MD
- Jackson, Mississippi
- Jean L. Fourcroy, MD, PhD
- Division of Metabolism and Endocrine Drug Products
- Food and Drug Administration
- Rockville, Maryland
- John A. Fracchia, MD
- Chief, Section of Urology
- Department of Surgery
- Lenox Hill Hospital
- New York, New York
- Jay Gillenwater, MD
- Professor and Chairman
- Department of Urology
- University of Virginia
- Charlottesville, Virginia
- James S. Goodlet, Jr., MD
- Urology Associates
- Marietta, Georgia
- John T. Grayhack, MD
- Department of Urology
- Northwestern University Medical School
- Chicago, Illinois
- Robert R. Hattery, MD
- Department of Radiology
- Mayo Clinic
- Rochester, Minnesota
- Charles E. Hawtrey, MD
- Department of Urology
- University Hospital
- University of Iowa
- Iowa City, Iowa
- Charles A. Isaac, MD
- Urologist
- Axtell Clinic
- Newton, Kansas
- Steven Kaplan, MD
- Department of Urology
- Columbian Presbyterian Medical Center
- New York, New York
- Karen A. Karlowicz, MSN, SURN
- School of Nursing
- College of Health Sciences
- Old Dominion University
- Norfolk, Virginia
- Warren W. Koontz, Jr., MD
- Division of Urology
- Medical College of Virginia
- Richmond, Virginia
- Frank Lawler, MD
- Associate Professor
- Department of Family Medicine
- University of Oklahoma
- Oklahoma City, Oklahoma
- Jay Lenker
- Vice-President of Research-Development
- Advanced Surgical Intervention, Inc.
- San Clemente, California
- Herbert Lepor, MD
- Professor and Chairman
- Department of Urology
- New York University School of Medicine
- New York, New York
- Harry C. Miller, Jr., MD, FACS
- Chairman
- Department of Urology
- George Washington University Medical Center
- Washington, DC
- Albert G. Mulley, MD
- General Internal Medicine
- Massachusetts General Hospital
- Boston, Massachusetts
- Joseph Oesterling, MD
- Department of Urology
- Mayo Clinic
- Rochester, New York
- William G. Plavcan, MD
- The Urological Center, P.A.
- Hagerstown, Maryland
- Howard Pollack, MD
- Professor of Radiology
- Section of Uroradiology
- School of Medicine
- University of Pennsylvania
- Philadelphia, Pennsylvania
- Patricia A. Prescott, PhD, RN
- Professor of Nursing
- University of Maryland at Baltimore
- Pratap K. Reddy, MD
- Professor of Urologic Surgery
- Interim Head and Clinical Chief, Urology Section
- Department of Urologic Surgery
- University of Minnesota Hospital and Clinic
- Minneapolis, Minnesota
- Robert A. Roth, MD
- Lahey Clinic Medical Center
- Burlington, Massachusetts
- Joseph W. Segura, MD
- Carl Rosen Professor of Urology
- Department of Urology
- Mayo Clinic
- Rochester, Minnesota
- Robert F. Slifkin, MD
- Associate Clinical Professor of Medicine
- Mount Sinai School of Medicine
- New York, New York
- Diane A. Smith, MSN, RN, CRNP
- Golden Horizons
- Newtown Square, Pennsylvania
- Robert J. Stanley, MD
- Professor and Chairman
- Department of Radiology University of Alabama at Birmingham
- Birmingham, Alabama
- Elizabeth Stoner, MD
- Executive Director Clinical Research
- Merck Research Laboratories
- Rahway, New Jersey
- Gary E. Striker, MD
- Director
- Division of Kidney, Urologic, and Hematologic Diseases
- National Institute of Diabetes and Digestive and Kidney Diseases
- National Institutes of Health
- Bethesda, Maryland
- Carralee A. Sueppel, CURN
- Clinical Nursing Specialist
- University of Iowa Hospitals and Clinics
- Iowa City, Iowa
- Albert P. Sutton, MD
- New Hyde Park, New York
- Celeste Symonette
- Reimbursement Manager
- American Medical Systems
- Pfizer Hospital Products Group
- Minnetonka, Minnesota
- Brent Treiger, MD
- Division of Urology
- Department of Surgery
- University of California at Los Angeles
- Los Angeles, California
- William R. Turner, Jr., MD
- Professor and Chairman
- Department of Urology
- Medical University of South Carolina
- Charleston, South Carolina
- E. Daracott Vaughn, Jr., MD
- Chairman, Department of Urology
- New York Hospital
- Cornell Medical Center
- New York, New York
- Datta G. Wagle, MD
- President
- New York State Urological Society
- Buffalo, New York
- James Wagner
- Microvasive Incorporated
- Watertown, Massachusetts

## Organizations [1]

- American Academy of Family Physicians
- American Academy of Osteopathy
- American Association of Retired Persons
- American College of Osteopathic Surgeons
- American College of Physicians
- American College of Radiology
- American Medical Association
- American Medical Review Research Center
- American Nurses Association
- American Society of Internal Medicine
- American Society of Post Anesthesia Nurses
- American Society of Radiologic Technologists
- American Urological Association Allied
- American Urological Association
- Association of Operating Room Nurses
- National Association of Hispanic Nurses
- National Medical Association
- Society of General Internal Medicine
- Society of University Urologists

These organizations provided peer review. Their reviews do not necessarily imply endorsement of the guideline.