# Glossary

Adrenergic. : A term used in reference to the secreting of, or to being characteristic of or activated by, epinephrine or substances with similar activity.

Alpha-adrenergic receptors. : Postulated sites on effector organs innervated by postganglionic adrenergic fibers of the sympathetic nervous system. They respond to norepinephrine and to certain stimulating or blocking agents. Alpha-1-adrenergic receptor blocking agents such as the drugs doxazosin, prazosin, and terazosin, when used in the treatment of BPH, relax bladder neck and prostate smooth muscle.

Androgens. : Substances conducive to masculinization, such as the hormone testosterone.

Artifacts. : Artificial features introduced in the course of processing.

Bladder (detrusor) muscle. : The smooth muscle in the wall of the urinary bladder that contracts the bladder and expels the urine.

Bladder neck contracture. : Narrowing or tightening of the bladder neck; sometimes occurs as a late complication of prostate surgery.

Bladder outlet obstruction.: An obstruction in the bladder outlet from either an anatomic or neurogenic cause.

Coils. : Coil-shaped devices under clinical investigation for the treatment of BPH and urethral stricture disease. Coils are metallic devices inserted in the prostatic urethra where they expand to maintain an open prostatic urethra to facilitate urine flow.

Confidence interval. : An interval indicating numerically the range of uncertainty for the probability of a particular outcome. A wide confidence interval, for example, 5-50 percent, represents considerable statistical uncertainty about the probability of the outcome to occur.

Confidence profile method. : A formal analytic technique based on Bayesian statistics (either Bayes' formula or the hierarchical Bayes' formula). This method permits combining of results from multiple studies with a variety of designs, enabling adjustment for perceived biases of external or internal validity. The confidence profile metho d produces a probability distribution for the parameter of interest rather than an odds ratio. This method was used in analysis of the BPH treatment data.

Creatinine. : A normal metabolic waste excreted in the urine. Creatinine is generally produced at a constant rate, and the clearance rate and the serum level are widely used as indices of kidney function.

Cronbach's alpha. : A summary measure of internal consistency reliability. Decompensation." Failure of organ to compensate for defect of structure or function.

Detrusor (musculi detrusor vesicae). : Bladder muscle.

Diverticulum. : A circumscribed pouch or sac of variable size.

Dysuria. : Painful or difficult urination.

Explicit approach. : An approach to guideline development which requires explicit description of the evidence considered, the consequences of different options, and the reasons for chosen options, as opposed to an implicit approach which relies solely on unexplained opinions of selected experts in a consensus panel.

Flowrate. : The volume per time unit of urinary fluid expelled via the urethra, expressed in milliliters per second.

Hematuria. : Blood in the urine.

Hydronephrosis. : Distention of the pelvis and calices of the kidney with urine as a result of obstruction of the ureter.

Hyperplasia. : Abnormal multiplication or increase in the number of normal cells in normal arrangement in a tissue.

Intravenous urography. : Roentgenography of a part of the urinary system made opaque by the injection of an opaque medium into the bloodstream; also called intravenous pyelography.

Macroscopic BPH. : BPH that is palpable during digital rectal examination.

Meatal stenosis. : Narrowing or stricture of an opening or passageway in the body.

Microscopic BPH. : BPH that is only detectable microscopically.

Micturition. : Urination.

Neurogenic bladder. : Dysfunction of the urinary bladder caused by a lesion of the central or peripheral nervous system.

Nocturia. : The involuntary loss of urine during sleep.

Nomogram. : A graph in which lines are graduated and aligned so that a straight edge crossing the lines allows the reading of unknown values on one line by means of known values on other lines.

Obstructive uropathy. : Any pathologic change in the urinary tract due to obstruction.

Orthostatic hypotension.: Low blood pressure with dizziness, fainting, and blurred vision upon standing or when standing motionless in a fixed position.

p value.: In statistics, a value very close to the probability of making a Type I error, the error of rejecting a true null hypothesis. A null hypothesis means no statistical significance, with any differences in populations or samples being due to chance. To make a Type I error is to find statistical significanc e when it is not there, as in mistaking chance results for treatment effects. For findings to be statistically significant, the probability of making a Type I error must be small, the smaller the better. The traditional cutoff value is 5 percent. If a p value is 5 percent or less (p<=0.05), the null hypothesis can be rejected and there is statistical significance.

Prostatism. : Symptom complex consisting of irritative symptoms (such as urgency, frequency, nocturia, and urge incontinence) and obstructive symptoms (such as hesitancy, weak stream, straining, prolonged micturition, urinary retention, and overflow incontinence).

Silent prostatism. : Anatomic prostatic hyperplasia and urodynamic evidence of obstruction without symptoms of prostatism.

Stents. : Devices similar to coils (defined above), with a slightly different design.

Tachyphylaxis.: Decreasing response to a drug.

Trabeculation. : Formation of fibrous bands of tissue (trabeculae).

Ultrasonography. : A noninvasive visualization technique that uses high frequency sound waves (ultrasound) aimed at a structure inside the body to produce an image (sonogram) of the internal structure or feature of interest.

Uninhibited detrusor contraction. : Involuntary contraction of the urinary detrusor.

Urethrocystoscopy. : Direct endoscopic viewing of the urethra with a cystoscope.

Urodynamic tests. : Tests designed to determine the anatomic and functional status of the urinary bladder and urethra. They include cystometry, electromyography, urethral pressure profilometry, uroflowmetry, and videourodynamics.