# Acronyms and Abbreviations

AHCPR: Agency for Health Care Policy and Research

AUA: American Urological Association

BLSA: Baltimore Longitudinal Study of Aging

BNC: Bladder neck contracture

BPH: Benign prostatic hyperplasia

CI: Confidence interval

CMG: Cystometrography

CT: Computerized tomography

DRE : Digital rectal examination

DRG: Diagnosis Related Group

FDA : Food and Drug Administration

HCFA: Health Care Financing Administration

HOCM : High osmolar contrast media

ICS : International Continence Society

IVU : Intravenous urography

JCSCM: Japanese Committee on the Safety of Contrast Media

LOCM: Low osmolar contrast media

NIDDK : National Institute of Diabetes and Digestive and Kidney Diseases

P[abd] : Intra-abdominal pressure

P[det]: Detrusor pressure

P[ves]: Intravesical pressure

PRO : Peer review organization

PSA : Prostate-specific antigen

PVR : Post void residual urine

Q[ave]: Average urinary flowrate

Q[max]: Maximum or peak urinary flowrate

r : Correlation coefficient

R : Urethral resistance

ROC: Receiver Operating Characteristic curve

RR: Risk ratio or relative risk

TUIP: Transurethral incision of the prostate

TURP: Transurethral resection of the prostate

UDC: Uninhibited detrusor contraction

VA: Department of Veterans Affairs

YAG: Yttrium aluminum garnet laser