# References

Aalkjer V. Transurethral resection/prostatectomy versus dilatation treatment in hypertrophy of the prostate II. Urol Int 1965;20:17-22.
Ablin RJ, Soanes WA, Bronson P, and Witebsky E. Precipitating antigens of the normal human prostate. J Reprod Fert 1970;22.573-574.
Abrams P, Blaivas JG, Stanton SL, Andersen JT. Standardization of terminology of lower urinary tract function. Neurourol Urodyn 1988;7:403-27.
Abrams P, Hollister P, Lawrence J, Doyle PT, Sherwood T, Whitaker RH. Bladder outflow obstruction treated with phenoxybenzamine. Preliminary note. Br J Urol 1982;54:530.
Abrams PH. Prostatism and prostatectomy: the value of urine flow rate measurement in the preoperative assessment for operation. J Urol 1977;117:70-1.
Abrams PH, Farrar DJ, Turner-Warwick RT, Whiteside CG, Feneley RC. The results of prostatectomy: a symptomatic and urodynamic analysis of 152 patients. J Urol 1979;121:640-2.
Abrams PH, Griffiths DJ. The assessment of prostatic obstruction from urodynamic measurements and from residual urine. Br J Urol 1979;51:129-34.
Adar R, Critchfield GC, Eddy DM. A confidence profile analysis of the results of femoropopliteal percutaneous transluminal angioplasty in the treatment of lower-extremity ischemia. J Vasc Surg 1989;10:57-67.
Andersen JT. Prostatism III. Detrusor hyperreflexia and residual urine. Clinical and urodynamic aspects and the influence of surgery on the prostate. Scand J Urol Nephrol 1982;16:25-30.
Andersen JT, Jacobsen O, Strandgaard L. The diagnostic value of intravenous pyelography in intravesical obstruction in males. Scand J Urol Nephrol 1977;11:225-30.
Andersen JT, Nordling J. Prostatism II. The correlation between cytso-urethroscopic, cystometric and urodynamic findings. Scand J Urol Nephrol 1980;14:23-7.
Armitage TG, Cooper EH, Newling DWW, Robinson MRG, Appleyard I. The value of the measurement of serum prostate specific antigen in patients with benign prostatic hyperplasia and untreated prostate cancer. Br J Urol 1988;62:584-9.
Arrighi HM, Guess HA, Metter EJ, Fozard JL. Symptoms and signs of prostatism as risk factors for prostatectomy. Prostate 1990;16:253-61.
Arvola I, Lilius HG. Transvesical prostatectomy a.m. Hryntschak. Ann Chir Gynaecol Fenn 1972;61:74-8.
Aubrey DA, Khosla T. The effect of 17-alpha-hydroxy-19-norprogesterone caproate (SH 582) on benign prostatic hypertrophy. Br J Surg 1971;58:648-52.
Ball AJ, Feneley RCL, Abrams PH. The natural history of untreated "prostatism." Br J Urol 1981;53:613-6.
Ball AJ, Smith PJB. The long-term effects of prostatectomy: a uroflowmetric analysis. J Urol 1982;128:538-40.
Balslev-Jorgensen J, Jensen KM-E, Bille-Brahe NE, Mogensen P. Uroflowmetry in asymptomatic elderly males. Br J Urol 1986;58:390-5.
Bandhauer K. Transurethral prostatectomy—complications. N Dev Biosc 1989;5:81-7.
Barry MJ. Medical outcomes research and benign prostatic hyperplasia. Prostate (Suppl) 1990;3:61-74.
Barry MJ. Physicians: taking the lead. Health Manage Q 1991;13(2):20-3.
Barry MJ, Fowler FJ Jr, O'Leary MP, Bruskewitz RC, Holtgrewe HL, Mebust WK, Cockett ATK, AUA Measurement Committee. The American Urological Association symptom index for benign prostatic hyperplasia. J Urol 1992a Nov;148:1549-57.
Barry MJ, Fowler FJ Jr, O'Leary MP, Bruskewitz RC, Holtgrewe HL, Mebust WK, AUA Measurement Committee. Correlation of the American Urological Association Symptom Index with self-administered versions of the Madsen-Iverson, Boyarsky and Maine Medical Assessment Program Symptom Indexes. J Urol 1992b Nov;148:1558-63.
Bauer DL, Garrison RW, McRoberts JW. The health and cost implications of routine excretory urography before transurethral prostatectomy. J Urol 1980;123:386-9.
Beacock CJM, Buck AC, Roberts EE. Bifluranol in the treatment of benign prostatic hyperplasia (BPH). Prostate 1985;7:357-61.
Beck AD. The Hryntschak prostatectomy II: a late review of 179 cases. J Urol 1970;103:778-82.
Beck AD, Gaudin HJ. The measurement and significance of the urinary flow rate. Aust N Z J Surg 1969;39:99-102.
Beck AD, Gaudin HJ. The Hryntschak prostatectomy I: a review of 1,346 cases. J Urol 1970;103:637-40.
Becker H, Ebeling L. Konservative therapie der benignen prostata-hyperplasie (BPH) mit Cernilton N. Ergebnisse einer plazebokontrollierten doppelblindstudie. Urologe [B]1988;28:301-6. (Ger).
Bell ET. Renal Diseases. Philadelphia: Lea & Febiger; 1950. p. 448.
Benson MC, Whang IS, Olsson CA, McMahon DJ, Cooner WH. The use of prostate specific antigen density to enhance the predictive value of intermediate levels of serum prostate specific antigen. J Urol 1992;147:817-21.
Benson MC, Whang IS, Pantuck A, Ring K, Kaplan SA, Olsson CA, Cooner WH. Prostate specific antigen density: a means of distinguishing benign prostatic hypertrophy and prostate cancer. J Urol 1992;147:815-6.
Berry SJ, Coffey DS, Walsh PC, Ewing LL. The development of human benign prostatic hyperplasia with age. J Urol 1984;132:474-9.
Birch NC, Hurst G, Doyle PT. Serial residual volumes in men with prostatic hypertrophy. Br J Urol 1988;62:571-5.
Birkhoff JD, Wiederhorn AR, Hamilton ML, Zinsser HH. Natural history of benign prostatic hypertrophy and acute urinary retention. Urology 1976;7:48-52.
Bissada NK, Finkbeiner AE, Redman JF. Accuracy of preoperative estimation of resection weight in transurethral prostatectomy. J Urol 1976;116:201-2.
Blue GD, Campbell JM. A clinical review of one thousand consecutive cases of retropubic prostatectomy. J Urol 1958;80:257-9.
Bollmann J, Zingg E. Retropubic prostatectomy. Prog Clin Biol Res 1976;6:59-65.
Bolt JW, Evans C, Marshall VR. Sexual dysfunction after prostatectomy. Br J Urol 1987;59(4):319-22.
Bonard M, de Almeida S, von Niederhausern W. Placebo-controlled double-blind study in human benign obstructive prostatic hypertrophy with flutamide. Eur Urol 1976;2(1):24-8.
Boreham PF, Braithwaite P, Milewski P, Pearson H. Alpha-adrenergic blockers in prostatism. Br J Surg 1977;64:756-7.
Bowers LM, Cross RR, Lloyd FA. Sexual function and urologic disease in the elderly male. J Am Geriatr Soc 1963;11:647-52.
Boyarsky S, Jones G, Paulson DF, Prout GR Jr. A new look at bladder neck obstruction by the Food and Drug Administration regulators: guide lines for investigation of benign prostatic hypertrophy. Trans Am Assoc Genitourin Surg 1976;68:29-32.
Brawer MK, Chetner MP, Beatie J, Buchner DM, Vessella RL, Lange PH. Screening for prostatic carcinoma with prostate specific antigen. J Urol 1992;147:841-5.
Brooks ME, Sidi AA, Hanani Y, Braf ZF. Ineffectiveness of phenoxybenzamine in treatment of benign prostatic hypertrophy. A controlled study. Urology 1983;21:474-8.
Bruskewitz RC, Iversen P, Madsen PO. Value of postvoid residual urine determination in evaluation of prostatism. Urology 1982;20:602-4.
Bruskewitz RC, Jensen KM-E, Iversen P, Madsen PO. The relevance of minimum urethral resistance in prostatism. J Urol 1983;129:769-71.
Bruskewitz RC, Larsen EH, Madsen PO, Dorflinger T. 3-year followup of urinary symptoms after transurethral resection of the prostate. J Urol 1986;136:613-5.
Buamah PK, Johnson P, Skillen AW. Comparative study of the clinical usefulness of prostate specific antigen and prostatic acid phosphatase in prostatic disease. Br J Urol 1988;62:581-3.
Buck AC, Cox R, Rees RWM, Ebling L, John A. Treatment of outflow tract obstruction due to benign prostatic hyperplasia with the pollen extract, Cernilton. A double-blind, placebo-controlled study. Br J Urol 1990;66:398-404.
Bundrick TJ, Katz PG. Excretory urography in patients with prostatism. Am J Roentgenol 1986;147:957-9.
Butler MR, Donnelly B, Komaranchat A. Intravenous urography in evaluation of acute retention. Urology 1978;12:464-6.
Caine M, Perlberg S, Gordon R. The treatment of benign prostatic hypertrophy with flutamide (SCH 13521): a placebo-controlled study. J Urol 1975;114:564-8.
Caine M, Perlberg S, Meretyk S. A placebo-controlled double-blind study of the effect of phenoxybenzamine in benign prostatic obstruction. Br J Urol 1978;50:551-4.
Caine M, Perlberg S, Shapiro A. Phenoxybenzamine for benign prostatic obstruction. Review of 200 cases. Urology 1981;17:542-6.
Carbin B-E, Larsson B, Lindahl O. Treatment of benign prostatic hyperplasia with phytosterols. Br J Urol 1990;66:639-41.
Carter HB, Pearson JD, Metter J, Brant LJ, Chan DW, Andres R, Fozard JL, Walsh PC. Longitudinal evaluation of prostate-specific antigen levels in men with and without prostate disease. JAMA 1992;267:2215-20.
Cascione CJ, Bartone FF, Hussain MB. Transabdominal ultrasound versus excretory urography in preoperative evaluation of patients with prostatism. J Urol 1987;137:883-5.
Castaneda F, Reddy P, Wasserman N, Hulbert J, Lund G, Letourneau JG, Hunter DW, Castaneda-Zuniga WR, Amplatz K. Benign prostatic hypertrophy: retrograde transurethral dilation of the prostatic urethra in humans. Work in progress. Radiology 1987;163:649-53.
Castro JE, Griffiths HJL, Edwards DE. A double-blind, controlled, clinical trial of spironolactone for benign prostatic hypertrophy. Br J Surg 1971;58(7):485-9.
Catalona WJ, Smith DS, Ratliff TL, Dodds KM, Coplen DE, Yuan JJJ, Petros JA, Andriole GL. Measurement of prostate-specific antigen in serum as a screening test for prostate cancer. N Engl J Med 1991;324:1156-61.
Champault G, Patel JC, Bonnard AM. A double-blind trial of an extract of the plant Serenoa repens in benign prostatic hyperplasia. Br J Clin Pharmacol 1984;18:461-2.
Chan DW, Bruzek DJ, Oesterling JE, Rock RC, Walsh PC. Prostate-specific antigen as a marker for prostatic cancer: a monoclonal and a polyclonal immunoassay compared. Clin Chem 1987;33:1916-29.
Chancellor MB, Blaivas JG, Kaplan SA, Axelrod S. Bladder outlet obstruction versus impaired detrusor contractility: the role of uroflow. J Urol 1991;145:810-2.
Charlson ME, Pompei P, Ales KL, MacKenzie CR. A new method of classifying prognostic comorbidity in longitudinal studies: development and validation. J Chronic Dis 1987;40:373-83.
Chilton CP, Morgan RJ, England HR, Paris AMI, Blandy JP. A critical evaluation of the results of transurethral resection of the prostate. Br J Urol 1978;50:542-6.
Chodak GW, Keller P, Schoenberg H. Routine screening for prostate cancer using the digital rectal examination. Prog Clin Biol Res 1988;269:87-98.
Chow W, Hahn D, Sandhu D, Slaney P, Henshaw R, Das G, Wells P. Multicentre controlled trial of indoramin in the symptomatic relief of benign prostatic hypertrophy. Br J Urol 1990;65:36-8.
Christofferson I, Christoffersen I, Moller I. Excretory urography: a superfluous routine examination in patients with prostatic hypertrophy. Eur Urol 1981;7(2):65-7.
Chybowski FM, Bergstralh EJ, Oesterling JE. The effect of digital rectal examination on the serum prostate-specific antigen concentration: results of a randomized study. J Urol 1992;148:83-6.
Clarke R. The prostate and the endocrines: a control series. Br J Urol 1937;9:254-71.
Concato J, Horwitz RI, Feinstein AR, Elmore JG, Schiff SF. Problems of comorbidity in mortality after prostatectomy. JAMA 1992;267:1077-82.
Cooner WH, Mosley BR, Rutherford CL Jr, Beard JH, Pond HS, Terry WJ, Igel TC, Kidd DD. Prostate cancer detection in a clinical urological practice by ultrasonography, digital rectal examination and prostate specific antigen. J Urol 1990;143:1146-54.
Craigen AA, Hickling JB, Saunders CR, Carpenter RG. Natural history of prostatic obstruction. J R Coll Gen Pract. 1969;18:226-32.
Crawford ED, Schutz MJ, Clejan S, Drago J, Resnick MI, Chodak GW, Gomella LG, Austenfeld M, Stone NN, Miles J, Thomson R. The effect of digital rectal examination on prostate-specific antigen levels. JAMA 1992;267:2227-8.
Cupp MR, Oesterling JE. Prostate-specific antigen, digital rectal examination, and transrectal ultrasonography: their roles in diagnosing early prostate cancer. Mayo Clin Proc 1993;68:297-306.
Dahlen CP, Goodwin WE. Sexual potency after perineal biopsy. J Urol 1957;77:660-9.
D'Ancona CAL, Netto NR Jr, Cara AM, Ikari O. Internal urethrotomy of the prostatic urethra or transurethral resection in benign prostatic hyperplasia. J Urol 1990;144:918-20.
Daughtry JD, Rodan BA, Bean WJ. Balloon dilation of prostatic urethra. Urology 1990;36:203-9.
Daver A, Soret JY, Coblentz Y, Allain YM, Cellier P, Chauveau P. The usefulness of prostate-specific antigen and prostatic acid phosphatase in clinical practice. Am J Clin Oncol 1988;11:53-60.
Davillas NE, Miliaresis A, Katsoulis A, Katatigiotis S. Observations on 1,000 Millin prostatectomies. Eur Urol 1978;4:100-2.
De Baker E, Lauwerijns A, Willem C. Sexual behavior after prostatectomy. Eur Urol 1977;3(5):295-8.
Delaere KPJ, Debruyne FMJ, Moonen WA. Extended bladder neck incision for outflow obstruction in male patients. Br J Urol 1983;55:225-8.
De Nicola P, Peruzza M. Sex in the aged. J Am Geriatr Soc 1974;22:380-2.
Di Mare JR, Fish SR, Harper JM, Politano VA. Residual urine in normal male subjects. J Urol 1963;96:180-1.
Donatucci C, Donohue R, Berger N, Raife M, Kreder K, Crawford E. Randomized clinical trial comparing balloon dilation to transurethral resection of prostate for benign prostatic hyperplasia. Urology 1993;42:42-9.
Donker PJ, Kakiailatu F. Preoperative evaluation of patients with bladder outlet obstruction with particular regard to excretory urography. J Urol 1978;120:685-6.
Donkervoort T, Zinner NR, Sterling AM, Donker PJ, Van Ness J, Ritter RC. Megestrol acetate in treatment of benign prostatic hypertrophy. Urology 1975;6:580-7.
Dorflinger T, Bruskewitz R, Jensen KM-E, Iversen P, Madsen PO. Predictive value of low maximum flow rate in benign prostatic hyperplasia. Urology 1986;27:569-73.
Dorflinger T, Oster M, Larsen JF, Walter S, Krarup T. Transurethral prostatectomy or incision of the prostate in the treatment of prostatism caused by small benign prostates. Scand J Urol Nephrol (Suppl) 1987;104:77-81.
Drach GW, Layton TN, Binard WJ. Male peak urinary flow rate: relationships to volume voided and age. J Urol 1979;122:210-4.
Drach GW, Steinbronn DV. Clinical evaluation of patients with prostatic obstruction: correlation of flow rates with voided, residual or total bladder volume. J Urol 1986;135:737-40.
Dunzendorfer U. Clinical experience: symptomatic management of BPH with terazosin. Urology (6 Suppl) 1988;32:27-31.
Ebbinghaus KD, Baur MP. Egrebnisse einer doppelblindstudie ueber die nirksambeit eines medikamentes zur konservativen behandlung des prostata-adenoms. ZFA 1977;53:1054-8. (Ger).
Eddy DM. Clinical decision making: from theory to practice. Guideline for policy statements: the explicit approach. JAMA 1990a;263:2239-43.
Eddy DM. Clinical decision making: from theory to practice. Comparing benefits and harms: the balance sheet. JAMA 1990b;263:2493-2505.
Eddy DM. The confidence profile method: A Bayesian method for assessing health technologies. Oper Res 1989;37(2):210-28.
Eddy DM. A manual for assessing health practices & designing practice policies: the explicit approach. Philadelphia: American College of Physicians; 1992. 126 p.
Eddy DM, Hasselblad V. FAST*PRO. Software for meta-analysis by the confidence profile method. San Diego (CA): Academic Press, Inc. Harcourt Brace Jovanovich; 1992. 196 p.
Eddy DM, Hasselblad V, Shachter R. A Bayesian method for synthesizing evidence: the confidence profile method. Int J Technol Assess Health Care 1990;6:31-55.
Edwards LE, Bucknall TE, Pittam MR, Richardson DR, Stanek J. Transurethral resection of the prostate and bladder neck incision: a review of 700 cases. Br J Urol 1985;57:168-71.
Ekman P. BPH epidemiology and risk factors. Prostate (Suppl) 1989;2:23-31.
Ercole CJ, Lange PH, Mathisen M, Chiou RK, Reddy PK, Vessella RL. Prostatic specific antigen and prostatic acid phosphatase in the monitoring and staging of patients with prostatic cancer. J Urol 1987;138:1181-4.
Fabricius PG, Weizert P, Dunzendorfer U, Hannaford JM, Maurath C. Efficacy of once-a-day terazosin in benign prostatic hyperplasia: a randomized, double-blind placebo-controlled clinical trial. Prostate (Suppl) 1990;3:85-93.
Farrar DJ. Pryor JS. The effect of bromocriptine in patients with benign prostatic hypertrophy. Br J Urol 1976;48:73-5.
Fidas A, Mackinlay JY, Wild SR, Chisholm GD. Ultrasound as an alternative to intravenous urography in prostatism. Clin Radiol 1987;38:479-82.
Filella X, Molina R, Jo J, Umbert B, Bedini JL, Ballesta AM. Clinical usefulness of prostate-specific antigen and prostatic acid phosphatase in patients with prostatic cancer. Tumor Biol 1990;11:289-94.
Finasteride Study Group. Finasteride (MK-906) in the treatment of benign prostatic hyperplasia. Prostate 1993;22:291-9.
Finkle AL, Moyers TG. Sexual potency in aging males IV. Status of private patients before and after prostatectomy. J Urol 1960a;84:152-7.
Finkle AL, Moyers TG. Sexual potency in aging males V. Coital ability following open perineal prostatic biopsy. J Urol 1960b;84:649-53.
Finkle AL, Moyers TG, Tobenkin MI. Sexual potency in aging males. 1. Frequency of coitus among clinic patients. JAMA 1959;170:1391-3.
Finkle AL, Prian DV. Sexual potency in elderly men before and after prostatectomy. JAMA 1966;196(2):139-43.
Finkle JE, Finkle PS, Finkle AL. Encouraging preservation of sexual function postprostatectomy. Urology 1975;6:697-702.
Folmer Andersen T, Bronnum-Hansen H, Sejr T, Roepstorff C. Elevated mortality following transurethral resection of the prostate for benign hypertrophy! But why? Med Care 1990;28:870-9.
Freeman JT. Sexual capacities in the aging male. Geriatrics 1961;16:37-43.
Geller J, Nelson CG, Albert JD, Pratt C. Effect of megestrol acetate on uroflow rates in patients with benign prostatic hypertrophy: double-blind study. Urology 1979;14:467-74.
George NJR, Feneley RCL, Roberts JBM. Identification of the poor risk patient with "prostatism" and detrusor failure. Br J Urol 1986;58:290-5.
Gerstenberg T, Blaabjerg J, Nielsen ML, Clausen S. Phenoxybenzamine reduces bladder outlet obstruction in benign prostatic hyperplasia. A urodynamic investigation. Invest Urol 1980;18:29-31.
Ghose RR. Prolonged recovery of renal function after prostatectomy for prostatic outflow obstruction. Br Med J 1990;300:1376-7.
Gill KP, Machan LS, Allison DJ, Williams G. Bladder outflow tract obstruction and urinary retention from benign prostatic hypertrophy treated by balloon dilatation. Br J Urol 1989;64:618-22.
Gleason DM, Bottaccini MR, Drach GW, Layton TN. Urinary flow velocity as an index of male voiding function. J Urol 1982;128:1363-7.
Glenski WJ, Klee GG, Bergstrahl EJ, Oesterling JE. Prostate-specific antigen: establishment of the reference range for the clinically normal prostate gland and the effect of digital rectal examination, ejaculation, and time on serum concentration. Prostate 1992;21(2):99-100.
Glynn RJ, Campion EW, Bouchard GR, Silbert JE. The development of benign prostatic hyperplasia among volunteers in the normative aging study. Am J Epidemiol 1985;121:78-90.
Gold FM, Hotchkiss RS. Sexual potency following simple prostatectomy. NY State J Med 1969;69:2987-9.
Goldenberg SL, Perez-Marrero RA, Lee LM, Emerson L. Endoscopic balloon dilation of the prostate: early experience. J Urol 1990;144:83-9.
Golomb J, Lindner A, Siegel Y, Korczak D. Variability and circadian changes in home uroflowmetry in patients with benign prostatic hyperplasia compared to normal controls. J Urol 1992;147:1044-7.
Goodwin MI, Chester JF, Jenkins JD. Acute urinary retention secondary to benign prostatic hyperplasia. Effect of alpha-adrenergic blockade. Urol Int 1986;41:430-1.
Gormley GJ, Stoner E, Bruskewitz RC, Imperato-McGinley J, Walsh PC, McConnell JD, Andriole GL, Geller J, Bracken BR, Tenover JS, et al. The effect of finasteride in men with benign prostatic hyperplasia. N Engl J Med 1992 Oct 22;327(17):1185-91.
Gregoir W. Haemostatic prostatic adenomectomy. Eur Urol 1978;4:1-8.
Griffiths DJ. Urethral resistance to flow: the urethral resistance relation. Abbreviated report. Urol Int 1975;30:28.
Griffiths HJL, Castro J. An evaluation of the importance of residual urine. Br J Radiol 1970;43:409-13.
Grino PB, Bruskewitz R, Blaivas JG, Siroky MB, Andersen JT, Cook T, Stoner E. Maximum urinary flow rate by uroflowmetry: automatic or visual interpretation. J Urol 1993;149(2):339-41.
Groshar D, Embon OM, Koritny ES, Sazbon A, Frenkel A. Radionuclide assessment of bladder-emptying function in normal male population and in patients before and after prostatectomy. Urology 1991;37:353-7.
Hald T. Urodynamics in benign prostatic hyperplasia: a survey. Prostate (Suppl) 1989;2:69-77.
Hara M, Inorre T, Fukuyama T. Some physico-chemical characteristics of gamma-seminoprotein, an antigenic component specific for human seminal plasma. Jpn J Legal Med 1971;25:322.
Hargreave TB, Stephenson TP. Potency and prostatectomy. Br J Urol 1977;49:683-8.
Harrison RH III, Boren JS, Robison JR. Dilutional hypoatremic shock: another concept of the transurethral prostatic resection reaction. J Urol 1956;75:95-110.
Harvey NA. Kidney tumors. J Urol 1947;57:669-92.
Hauri D. Das leben nachder prostatektomie. Urol Int 1982;37:271-6. (Ger)[AUTH]
Haylen BT, Ashby D, Sutherst JR, Frazer MI, West CR. Maximum and average urine flow rates in normal male and female populations—the Liverpool nomograms. Br J Urol 1989;64:30-8.
Hedlund H, Andersson K-E, Ek A. Effects of prazosin in patients with benign prostatic obstruction. J Urol 1983;130:275-8.
Hedlund H, Ek A. Ejaculation and sexual function after endoscopic bladder neck incision. Br J Urol 1985;57:164-7.
Hellstrom P, Lukkarinen O, Kontturi M. Bladder neck incision or transurethral electroresection for the treatment of urinary obstruction caused by a small benign prostate? A randomized urodynamic study. Scand J Urol Nephrol 1986;20:187-92.
Hendrikx AJM, Doesburg WH, Reintjes AGM, Strijk SP, Debruyne FMJ. Effectiveness of ultrasound in the preoperative evaluation of patients with prostatism. Prostate 1988;13:199-208.
Hinman F, Cox CE. Residual urine volume in normal male subjects. J Urol 1967;97:641-5.
Hohenfellner R. Suprapubic prostatectomy. In: Prostatic diseases. New York: Alan R. Liss, Inc.; 1976. p. 49-57.
Holtgrewe HL, Mebust WK, Dowd JB, Cockett ATK, Peters PC, Proctor C. Transurethral prostatectomy: practice aspects of the dominant operation in American urology. J Urol 1989;141:248-53.
Holtgrewe HL, Valk WL. Factors influencing the mortality and morbidity of transurethral prostatectomy: a study of 2,015 cases. J Urol 1962;87:450-9.
Holtgrewe HL, Valk WL. Late results of transurethral prostatectomy. J Urol 1964;92:51-5.
Hudson MA, Bahnson RR, Catalona WJ. Clinical use of prostate specific antigen in patients with prostate cancer. J Urol 1989;142:1011-7.
Iacovou JW, Dunn M. Indoramin—an effective new drug in the management of bladder outflow obstruction. Br J Urol 1987;60:526-8.
Ireton RC, Krieger JN, Cardenas DD, Williams-Burden B, Kelly E, Souci T, Chapman WH. Bladder volume determination using a dedicated, portable ultrasound scanner. J Urol 1990;143:909-11.
Isaacs JT. Importance of the natural history of benign prostatic hyperplasia in the evaluation of pharmacologic intervention. Prostate (Suppl) 1990;3:1-7.
Isaacs JT, Coffey DS. Etiology and disease process of benign prostatic hyperplasia. Prostate (Suppl) 1989;2:33-50.
Jardin A, Bensadoun H, Delauche-Cavallier MC, Attali P, and the BPH-ALF Group. Alfuzosin for treatment of benign prostatic hypertrophy. Lancet 1991;337:1457-61.
Jensen KM-E, Andersen JT. Urodynamic implications of benign prostatic hyperplasia. Urologe [A] 1990;29:1-4.
Jensen KM-E, Bruskewitz RC, Iversen P, Madsen PO. Spontaneous uroflowmetry in prostatism. Urology 1984;24:403-9.
Jensen KM-E, Jorgensen JB, Mogensen P. Urodynamics in prostatism I. Prognostic value of uroflowmetry. Scand J Urol Nephrol 1988a;22:109-17.
Jensen KM-E, Jorgensen JB, Mogensen P. Urodynamics in prostatism II. Prognostic value of pressure-flow study combined with stop-flow test. Scand J Urol Nephrol (Suppl) 1988b;114:72-7.
Jensen KM-E, Jorgensen JB, Mogensen P. Urodynamics in prostatism III. Prognostic value of medium-fill water cystometry. Scand J Urol Nephrol (Suppl) 1988c;114:78-83.
Jensen KM-E, Jorgensen JB, Mogensen P. Urodynamics in prostatism IV. Search for prognostic patterns as evaluated by linear discriminant analysis. Scand J Urol Nephrol (Suppl) 1988d;114:84-6.
Jensen KM-E, Madsen PO. Candicidin treatment of prostatism: a prospective double-blind placebo-controlled study. Urol Res 1983;11:7-10.
Juul N, Torp-Pedersen S, Nielsen H. Abdominal ultrasound versus intravenous urography in the evaluation of infravesically obstructed males. Scand J Urol Nephrol 1989;23:89-92.
Kadow C, Abrams PH. A double-blind trial of the effect of beta-sitosteryl glucoside (NA184) in the treatment of benign prostatic hyperplasia. Eur Urol 1986;12:187-9.
Kadow C, Feneley RCL, Abrams PH. Prostatectomy or conservative management in the treatment of benign prostatic hypertrophy? Br J Urol 1988;61:432-4.
Kaplan MH, Feinstein AR. The importance of classifying initial co-morbidity in evaluating the outcome of diabetes mellitus. J Chronic Dis 1974;27:387-404.
Katayama H, Yamaguchi K, Kozuka T, Takashima T, Seez P, Matsuura K. Adverse reactions to ionic and nonionic contrast media. A report from the Japanese Committee on the Safety of Contrast Media. Radiology 1990;175:621-8.
Katz PG, Greenstein A, Ratliff JE, Marks S, Guice J. Transurethral incision of the bladder neck and prostate. J Urol 1990;144:694-6.
Kawabe K, Niijima T. Use of an alpha 1-blocker, YM-12617, in micturition difficulty. Urol Int 1987;42:280-4.
Kawabe K, Ueno A, Takimoto Y, Aso Y, Kato H, and YM617 clinical study group. Use of an alpha 1-blocker, YM617, in the treatment of benign prostatic hypertrophy. J Urol 1990;144:908-12.
Keane PF, Charig CR, Hudd C, Shah PJR, Kellett MJ, Boyle J, Wickham JEA, O'Donoghue EPN. Balloon dilatation of the prostate: technique and early results. Br J Urol 1990;65:354-6.
Kelly MJ, Roskamp D, Leach GE. Transurethral incision of the prostate: a preoperative and postoperative analysis of symptoms and urodynamic findings. J Urol 1989;142:1507-9.
Kinnison ML, Powe NR, Steinberg EP. Results of randomized controlled trials of low- versus high-osmolality contrast media. Radiology 1989;170:381-9.
Kinsey A. Sexual behavior in the human male. Philadelphia (PA): W.B. Saunders Co; 1948. xv, 804 p.
Kirby RS, Coppinger SWC, Corcoran MO, Chapple CR, Flannigan M, Milroy EJG. Prazosin in the treatment of prostatic obstruction. A placebo-controlled study. Br J Urol 1987;60:136-42.
Klein L, Perez-Marrero R, Bowers GW, Ludwig JJ, Herwig K. Transurethral cystoscopic balloon dilation of the prostate. J Endourol 1990;4(2):183-91.
Klein LA, Lemming B. Balloon dilatation for prostatic obstruction. Long-term follow-up. Urology 1989;33:198-201.
Kreel L, Elton A, Habershon R, Mason AMS, Meade TW. Use of intravenous urography. Br Med J 1974;4:31-3.
Kuo HC, Tsai TC. The predictive value of urine flow rate and voiding pressure in the operative outcome of benign prostatic hypertrophy. Taiwan I Hsueh Hui Tsa Chih 1988;87:323-30.
Lange PH, Ercole CJ, Lightner DJ, Fraley EE, Vessella R. The value of serum prostate specific antigen determinations before and after radical prostatectomy. J Urol 1989;141:873-9.
Larsen EH, Dorflinger T, Gasser TC, Graversen PH, Bruskewitz RC. Transurethral incision versus transurethral resection of the prostate for the treatment of benign prostatic hypertrophy. A preliminary report. Scand J Urol Nephrol (Suppl) 1987;104:83-6.
Layton TN, Drach GW. Selectivity of peak versus average male urinary flow rates. J Urol 1981;125:839-41.
Leary FJ, Myers RP, Greene LF, Hartman GW. The value of excretory urography as a screening test in asymptomatic patients. J Urol 1972;107:850-1.
Lee F, Littrup PJ, Torp-Pedersen ST, Mettlin C, McHugh TA, Gray JM, Kumasaba GH, McLeary RD. Prostate cancer: comparison of transrectal US and digital rectal examination for screening. Radiology 1988;168:389-94.
Lenko J. Millin's retropubic prostatectomy. A clinical study. Int Urol Nephrol 1977;9:25-32.
Lenko J, Cieslinski S. Millin's retropubic prostatectomy: report of 233 cases. Br J Urol 1965;37:450-4.
Lentz HC, Mebust WK, Foret JD, Melchior J. Urethral strictures following transurethral prostatectomy: review of 2,223 resections. J Urol 1977;117:194-6.
Lepor H, Auerbach S, Puras-Baez A, Narayan P, Soloway M, Lowe F, Moon T, Leifer G, Madsen P. A randomized, placebo-controlled multicenter study of the efficacy and safety of terazosin in the treatment of benign prostatic hyperplasia. J Urol 1992;148:1467-74.
Lepor H, Henry D, Laddu AR. The efficacy and safety of terazosin for the treatment of symptomatic BPH. Prostate 1991;18:345-55.
Lepor H, Knapp-Maloney G. Outcome assessment of terazosin for benign prostatic hyperplasia (BPH): 18 month follow-up. Abstract #204. J Urol (Suppl) 1991;145:263A.
Lepor H, Knapp-Maloney G, Sunshine H. A dose titration study evaluating terazosin, a selective, once-a-day alpha-1-blocker for the treatment of symptomatic benign prostatic hyperplasia. J Urol 1990;144:1393-8.
Lepor H, Rigaud G. The efficacy of transurethral resection of the prostate in men with moderate symptoms of prostatism. J Urol 1990;143(3):533-7.
Lepor H, Sypherd D, Machi G, Derus J. Randomized double-blind study comparing the effectiveness of balloon dilation of the prostate and cystoscopy for the treatment of symptomatic benign prostatic hyperplasia. J Urol 1992;147(3):639-44.
Lesiewicz H, Cieslinski S. Millin's retropubic prostatectomy: a clinical study. Int. Urol. Nephrol 1985;17:341-8.
Li MK, Ng ASM. Bladder neck resection and transurethral resection of the prostate: a randomized prospective trial. J Urol 1987;138:807-9.
Libman E, Fichten CS. Prostatectomy and sexual function. Urology 1987;29:467-78.
Libman E, Fichten CS, Creti L, Weinstein N, Amsel R, Brender W. Transurethral prostatectomy: differential effects of age category and presurgery sexual functioning on postprostatectomy sexual adjustment. J Behav Med 1989;12:469-85.
Lich R. Retropubic prostatectomy: a review of 678 patients. J Urol 1954;72:434-8.
Lilienfeld RM, Berman M, Khedkar M, Sporer A. Comparative evaluation of intravenous urogram and ultrasound in prostatism. Urology 1985;26:310-2.
Lindner A, Golomb J, Korzcak D, Keller T, Siegel Y. Effects of prostatectomy on sexual function. Urology 1991;38:26-8.
Lindner A, Siegel YI, Saranga R, Korzcak D, Matzkin H, Braf Z. Complications in hyperthermia treatment of benign prostatic hyperplasia. J Urol 1990;144:1390-2.
Lucke B, Schlumberger HG. Tumors of the kidney, renal pelvis and ureter. Atlas of Tumor Pathology, 1957. Washington, DC: Armed Forces Institute of Pathology. p. 11-20.
Lund B-L, Dingsor E. Benign obstructive prostatic enlargement. A comparison between the results of treatment by transurethral electro-resection and the results of open surgery. Scand J Urol Nephrol 1976;10:33-8.
Lytton B, Emery JM, Harvard BM. The incidence of benign prostatic obstruction. J Urol 1968;99:639-45.
Macky W. Hryntschak prostatectomy: experiences with 300 consecutive cases. Br J Urol 1961;33:19-23.
Madorsky ML, Ashamalla MG, Schussler I, Lyons HR, Miller GH Jr. Post-prostatectomy impotence. J Urol 1976;115:401-3.
Madsen PO, Dorflinger T, Frimodt-Moller PC, Jensen KM-E. Candicidin in treatment of benign prostatic hypertrophy. J Urol 1984;132:1235-8.
Madsen PO, Iversen P. A point system for selecting operative candidates. In: Hinman F Jr., editor. Benign prostatic hypertrophy. New York: Springer Verlag; 1983. p. 763-5.
Magasi P, Vegh A. One thousand cases of prostatectomy. Acta Chir Hung 1984;25:63-74.
Malenka DJ, Roos N, Fisher ES, McLerran D, Whaley FS, Barry MJ, Bruskewitz R, Wennberg JE. Further study of the increased mortality following transurethral prostatectomy: a chart-based analysis. J Urol 1990;144:224-8.
Malone PR, Cook A, Edmonson R, Gill MW, Shearer RJ. Prostatectomy: patients' perception of long-term follow up. Br J Urol 1988;61:234-8.
Mansson W, Sundin T, Gullberg B. Evaluation of a synthetic vasopressin analogue for treatment of nocturia in benign prostatic hypertrophy—a double-blind study. Scand J Urol Nephrol 1980;14:139-41.
Marshall V, Singh M, Blandy JP. Is urography necessary for patients with acute retention of urine before prostatectomy? Br J Urol 1974;46:73-6.
Martorana G, Giberti C, Damonte P, Ciprandi G, Dirienzo W, Giuliana L. The effect of prazosin in benign prostatic hypertrophy, a placebo controlled double-blind study. IRCS Med Science 1984;12:11-2.
Massagli TL, Jaffe KM, Cardenas DD. Ultrasound measurement of urine volume of children with neurogenic bladder. Dev Med Child Neurol 1990;32:314-8.
Matos-Ferreira A, Corte-Real J, Palma J, Durao V. The effect of bromocriptine in benign prostatic hypertrophy and vesicosphincteric dynamics. Br J Urol 1987;60:143-9.
Matthews PN, Quayle JB, Joseph AEA, Williams JE, Wilkinson KW, Riddle PR. The use of ultrasound in the investigation of prostatism. Br J Urol 1982;54:536-8.
McCarthy ME, Willard M. Health care prostate therapies. Shearson, Lehman, and Hutton 1990 Jun 5;1-12.
McClennan BL. Ionic versus nonionic contrast media: safety, tolerance, and rationale for use. Urol Radiol 1990;11:200-2.
McConnell JD. Medical management of benign prostatic hyperplasia with androgen suppression. Prostate (Suppl) 1990;3:49-59.
McLoughlin J, Gill KP, Abel PD, Williams G. Symptoms versus flow rates versus urodynamics in the selection of patients for prostatectomy. Br J Urol 1990;66:303-5.
McLoughlin J, Keane PF, Jager R, Gill KP, Machann L, Williams G. Dilatation of the prostatic urethra with 35 mm balloon. Br J Urol 1991;67:177-81.
McPherson K, Wennberg JE, Hovind OB, Clifford P. Small area variations in the use of common surgical procedures: an international comparison of New England, England and Norway. N Engl J Med 1982;307:1310-4.
Mebust WK, Holtgrewe HL, Cockett ATK, Peters PC, and Writing Committee. Transurethral prostatectomy: immediate and postoperative complications. A cooperative study of 13 participating institutions evaluating 3,885 patients. J Urol 1989;141:243-7.
Melchior J, Valk WL, Foret JD, Mebust WK. Transurethral prostatectomy: computerized analysis of 2,223 consecutive cases. J Urol 1974a;112:634-42.
Melchior J, Valk WL, Foret JD, Mebust WK. Transurethral prostatectomy in the azotemic patient. J Urol 1974b;112:643-6.
Merck, Sharp & Dohme Research Laboratories. Proscar (finasteride) for the treatment of benign prostatic hyperplasia. Presentation before the Endocrinologic and Metabolic Drugs Advisory Committee, Food and Drug Administration; 1992 Feb 4; National Institutes of Health, Bethesda, MD. Transcript available from: Documents Management Branch, FDA, Rockville, MD.
Messing EM, Young TB, Hunt VB. The significance of asymptomatic microhematuria in men 50 or more years old: findings of a home screening study using urinary dipsticks. J Urol 1987;137:919-22.
Meyhoff HH, Ingemann L, Nordling J, Hald T. Accuracy in preoperative estimation of prostatic size. A comparative evaluation of rectal palpation, intravenous pyelography, urethral closure pressure profile recording and cystourethroscopy. Scand J Urol Nephrol 1981;15:45-51.
Meyhoff HH, Nordling J. Long term results of transurethral and transvesical prostatectomy. A randomized study. Scand J Urol Nephrol 1986;20:27-33.
Meyhoff HH, Nordling J, Hald T. Economy in transurethral prostatectomy. Scand J Urol Nephrol 1985;19:17-20.
Meyhoff HH, Nordling J, Hald T. Urodynamic evaluation of transurethral versus transvesical prostatectomy. A randomized study. Scand J Urol Nephrol 1984;18:27-35.
Mobb GE, Moisey CU. Long-term follow-up of unilateral bladder neck incision. Br J Urol 1988;62:160-2.
Mohr DN, Offord KP, Melton LJ. Isolated asymptomatic microhematuria: a cross sectional analysis of test-positive and test-negative patients. J Gen Intern Med 1987;2:318-24.
Mohr DN, Offord KP, Owen RA, Melton LJ. Asymptomatic microhematuria and urologic disease. JAMA 1986;256:224-9.
Moller-Nielsen C, Lundhus E, Moller-Madsen B, Norgaard JP, Simonsen OH, Hansen SL, Birkler N. Sexual life following "minimal" and "total" transurethral prostatic resection. Urol Int 1985;40:3-4.
Morrison JD. Help or habit? Excretion urography before prostatectomy. Br J Clin Pract 1980;34:239-41.
Mukamel E, Nissenkorn I, Boner G, Servadio C. Occult progressive renal damage in the elderly male due to benign prostatic hypertrophy. J Am Geriatr Soc 1979;27:403-6.
Muzafer MH. Pre-prostatectomy intravenous urography—is it a must? Int Urol Nephrol 1986;18(1):65-9.
Neal DE, Styles RA, Powell PH, Ramsden PD. Relationship between detrusor function and residual urine in men undergoing prostatectomy. Br J Urol 1987;60:560-6.
Newman G, Nichols CR. Sexual activities and attitudes in older persons. JAMA 1960;173:33-5.
Nicoll GA, Riffle GN, Anderson FO. Suprapubic prostatectomy. The removable purse string: a continuing comparative analysis of 300 consecutive cases. J Urol 1978;120:702-4.
Nielsen HO. Transurethral prostatotomy versus transurethral prostatectomy in benign prostatic hypertrophy. A prospective randomised study. Br J Urol 1988;61:435-8.
Nishio K, Kass I, Levine MH. Survey of 500 consecutive routine abdominal roentgenograms of adults hospitalized for chest disease. Dis Chest 1962;41:415-21.
Nissenkorn I, Savion M, Servadio C. Renal and bladder function recovery after prostatectomy in patients with a chronic residual urine of above 1,000 mL. Eur Urol 1988;14:434-6.
Ochsner SF, Buchtel BC, Little EH. Diagnoses made in 10,000 consecutive excretory urographies. J La State Med Soc 1965;117:191-3.
Oesterling JE. Prostate specific antigen: a critical assessment of the most useful tumor marker for adenocarcinoma of the prostate. J Urol 1991;145:907-23.
Oesterling JE, Chan DW, Epstein JI, Kimball AW, Bruzek DJ, Rock RC, Brendler CB, Walsh PC. Prostate specific antigen in the preoperative and postoperative evaluation of localized prostatic cancer treated with radical prostatectomy. J Urol 1988;139:766-72.
Orandi A. Transurethral incision of prostate (TUIP): 646 cases in 15 years—a chronological appraisal. Br J Urol 1985;57:703-7.
Orandi A. Transurethral incision of prostate compared with transurethral resection of prostate in 132 matching cases. J Urol 1987;138:810-5.
Orandi A. Transurethral resection versus transurethral incision of the prostate. Urol Clin North Am 1990;17:601-12.
Orkin L. Efficacy of candicidin in benign prostatic hypertrophy. Urology 1974;4(1):80-4.
Ostri P, Swartz R, Meyhoff H-H, Petersen JH, Lindgard G, Frimodt-M oller C, Andersson T, Nielsen MS. Antiandrogenic treatment of benign prostatic hyperplasia: a placebo controlled trial. Urol Res 1989;17:29-33.
Partin AW, Carter HB, Chan DW, Epstein JI, Oesterling JE, Rock RC, Weber JP, Walsh PC. Prostate specific antigen in the staging of localized prostate cancer: influence of tumor differentiation, tumor volume and benign hyperplasia. J Urol 1990;143:747-52.
Parys BT, Machin DG, Woolfenden KA, Parsons KF. Chronic urinary retention—a sensory problem? Br J Urol 1988;62:546-9.
Pearlman CK, Kobashi LI. Frequency of intercourse in men. J Urol 1972;107:298-301.
Pinck BD, Corrigan MJ, Jasper P. Pre-prostatectomy excretory urography: does it merit the expense? J Urology 1980;123:390-1.
Powe NR, Steinberg EP, Erickson JE, Moore RD, Smith CR, White RI, Brinker JA, Fishman EK, Zinreich SJ, Kinnison ML, Anderson GF. Contrast medium-induced adverse reactions: economic outcome. Radiology 1988;169:163-8.
Powell PH, Smith PJB, Feneley RCL. The identification of patients at risk from acute retention. Br J Urol 1980;52:520-2.
Preventive Services Task Force (US). Guide to clinical preventive services: an assessment of the effectiveness of 169 interventions. Baltimore: Williams & Wilkins; 1989. 419 p.
Purkiss SF. Assessment of residual urine in men following catheterisation. Br J Urol 1990;66:279-80.
Ramsay JW, Scott GI, Whitfield HN. A double-blind controlled trial of a new a-1 blocking drug in the treatment of bladder outflow obstruction. Br J Urol 1985;57:657-9.
Resnick MI, Jackson JE, Watts LE, Boyce WH. Assessment of the antihypercholesterolemic drug, Probucol, in benign prostatic hyperplasia. J Urol 1983;129:206-9.
Roehrborn CG, Chinn HK, Fulgham PF, Simpkins KL, Peters PC. The role of transabdominal ultrasound in the preoperative evaluation of patients with benign prostatic hypertrophy. J Urol 1986;135:1190-3.
Rollema HJ, van Mastrigt R. Objective analysis of prostatism: a clinical application of the computer program CLIM. Neurourol Urodyn 1991;10:71-6.
Rollema HJ, van Mastrigt R, Janknegt RA. Urodynamic assessment and quantification of prostatic obstruction before and after transurethral resection of the prostate: standardization with the aid of the computer program CLIM. Urol Int (Suppl) 1991;1:52-4.
Ronchi F, Margonato A, Ceccardi R, Rigatti P, Rossini BM. Symptomatic treatment of benign prostatic obstruction with nicergoline: a placebo controlled clinical study and urodynamic evaluation. Urol Res 1982;10:131-4.
Roos NP, Ramsey EW. A population-based study of prostatectomy: outcomes associated with differing surgical approaches. J Urol 1987;137:1184-8.
Roos NP, Wennberg JE, Malenka DJ, Fisher ES, McPherson K, Andersen TF, Cohen MM, Ramsey E. Mortality and reoperation after open and transurethral resection of the prostate for benign prostatic hyperplasia. N Engl J Med 1989;320:1120-4.
Rosenbaum HD, Lieber A, Hanson DJ, Pellegrino ED. A routine survey roentgenogram of the abdomen on 500 consecutive patients over 40 years of age. Am J Roentgenol Radium Ther Nucl Med 1964;91:903-9.
Ruutu ML, Hansson E, Juusela HE, Permi JE, Rusk JI, Sotarauta MT, Talja MT, Wuokko EJ, Mattila MJ. Efficacy and side-effects of prazosin as a symptomatic treatment of benign prostatic obstruction. Scand J Urol Nephrol 1991;25:15-9.
Ryall RR, Marshall VR. Normal peak urinary flow rates obtained from small voided volumes can provide a reliable assessment of bladder function. J Urol 1982;127:484-8.
Sacks SH, Aparicio SAJR, Bevan A, Oliver DO, Will EJ, Davison AM. Late renal failure due to prostatic outflow obstruction: a preventable disease. Br Med J 1989;298:156-9.
Salvaris M. Retropubic prostatectomy: an evaluation of 1200 operations. Med J Aust 1969;1:370-6.
Sarmina I, Resnick MI. Obstructive uropathy in patients with benign prostatic hyperplasia. J Urol 1989;141:866-9.
Schafer W, Noppeney R, RUbben H, Lutzeyer W. The value of free flow rate and pressure/flow-studies in the routine investigation of BPH patients. Neurourol Urodyn 1988;7:219-21.
Schafer W, RUbben H, Noppeney R, Deutz F-J. Obstructed and unobstructed prostatic obstruction. A plea for urodynamic objectivation of bladder outflow obstruction in benign prostatic hyperplasia. World J Urol 1989;6:198-203.
Schwab SJ, Hlatky MA, Pieper KS, Davidson CJ, Morris KG, Skelton TN, Bashore TM. Contrast nephrotoxicity: a randomized controlled trial of a nonionic and an ionic radiographic contrast agent. N Engl J Med 1989;320:149-53.
Scott FB, Cardus D, Quesada EM, Riles T. Uroflowmetry before and after prostatectomy. South Med J 1967;60:(Pt. 2)948-52.
Scott R, McIlhaney JS. Voiding rates in normal adults. J Urol 1961;85:980-2.
Sertcelik MN, Unal S, Ozgur S, Imamoglu A. Prazosin, a selective alpha, receptor blocker, in the treatment of benign prostatic hypertrophy. Curr Ther Res 1990;48:1066-74.
Shilcher H, Sauter M, Janssen H. Zum wirksamkeitsnachweis von phytopharmaka am beispeil von prosta-fink. Arztezeitschrift fuer naturheilverfahren. 1985;26(3)177-82. (Ger).
Shipman JJ, Akilie AN. Treatment by prostatic injection of acute urinary retention due to prostatic hyperplasia. Br Med J 1967;2:418-9.
Shoukry I, Susset JG, Elhilali MM, Dutartre D. Role of uroflowmetry in the assessment of lower urinary tract obstruction in adult males. Br J Urol 1975;47: (Pt 2)559-66.
Sidney S, Quesenberry CP, Sadler MC, Cattolica EV, Lydick EG, Guess HA. Reoperation and mortality after surgical treatment of benign prostatic hypertrophy in a large prepaid medical care program. Med Care 1992;30:117-25.
Sidney S, Quesenberry C, Sadler MC, Lydick EG, Guess HA, Cattolica EV. Risk factors for surgically treated benign prostatic hyperplasia in a prepaid health care plan. Urology (Suppl 1) 1991;38:13-9.
Simonsen O, Moller-Madsen B, Dorflinger T, Norg aard JP, Jorgensen HS, Lundhus E: The significance of age on symptoms and urodynamic and cystoscopic findings in benign prostatic hypertrophy. Urol Res 1987;15:355-8.
Singh M, Tresidder GC, Blandy JP. The evaluation of transurethral resection for benign enlargement of the prostate. Br J Urol 1973;45:93-102.
Siroky MB, Olsson CA, Krane RJ. The flow rate nomogram I: development. J Urol 1979;122:665-8.
Siroky MB, Olsson CA, Krane RJ. The flow rate nomogram II: clinical correlation. J Urol 1980;123:208-10.
Smith HR, Memon A, Smart CJ, Dewbury K. The value of permixon in benign prostatic hypertrophy. Br J Urol 1986;58:36-40.
Smith JC. Urethral resistance to micturition. Br J Urol 1968;40:125-56.
Solomon DJ, Van Niekerk JPDV. Ultrasonography should replace intravenous urography in the pre-operative evaluation of prostatism. S Afr Med J 1988;74:407-8.
Sonnenschein R. Untersuchungen der wirksamkeit eines prostatotropen phytotherapeutikums (urtica plus) bei benigner prostatahyperplasie und prostatitis-eine prospektive multizentrische studie. Urologe [B] 1987;27:232-7. (Ger).
Spangberg A, Terio H, Ask P, Engberg A. Pressure/flow studies preoperatively and postoperatively in patients with benign prostatic hypertrophy: estimation of the urethral pressure/flow relation and urethral elasticity. Neurourol Urodyn 1991;10:139-67.
Sporer A, Cohen G, Kamat MH, Seebode JJ. Candicidin physiologic effect on prostate. Urology 1975;6(3):298-304.
Stamey TA, Yang N, Hay AR, McNeal JE, Freiha FS, Redwine E. Prostate-specific antigen as a serum marker for adenocarcinoma of the prostate. N Engl J Med 1987;317:909.
Stavropoulos N, Christodoulou K, Chamilos E, Karidis G, Karagiotas N, Yiannopoulos P. Evaluation of patients with benign prostatic hypertrophy: IVU versus ultrasound. J R Coll Surg Edinb 1988;33:140-2.
Stearns DB. Retropubic prostatectomy, 1947-1960: A critical evaluation. J Urol 1961;85:322-8.
Stephenson WP, Chute CG, Guess HA, Schwartz S, Lieber M. Incidence and outcome of surgery for benign prostatic hyperplasia among residents of Rochester, Minnesota: 1980-87. Urology (Suppl 1) 1991;38:32-42.
Stoller ML, Millard RJ. The accuracy of a catheterized residual urine. J Urol 1989;141:15-6.
Stone NN. Flutamide in treatment of benign prostatic hypertrophy. Urology (Suppl 4) 1989;34:64-8;discussion 87-96.
Susset JG, Picker P, Kretz M, Jorest R. Critical evaluation of uroflowmeters and analysis of normal curves. J Urol 1973;109:874-8.
Taylor WN, Kaylor WM, Taylor JN. Retropubic and suprapubic prostatectomy: comparative clinical study. J Urol 1955;74:129-37.
Taylor Z, Krakauer H. Mortality and reoperation following prostatectomy: outcomes in a medicare population. Urology (Suppl 1) 1991;38:27-31.
Thompson IM, Ernst JJ, Gangai MP, Spence CR. Adenocarcinoma of the prostate: results of routine urological screening. J Urol 1984;132:690-2.
US decennial life tables. State life tables;v.1,AL-MO;v.2,MT-WY, 1990 issue. Life expectancy; mortality (US). PHS 90-1151. Hyattsville (MD): US Department of Health and Human Services, Public Health Service, National Center for Health Statistics.
Van Poppel H, Boeckx G, Westlinck KJ, Westelinck KJ, Vereecken RL, Baert L. The efficacy of bromocriptine in benign prostatic hypertrophy. A double-blind study. Br J Urol 1987;60(2):150-2.
Vereecken RL. Sexual activity of men presenting with prostatism: effect of prostatectomy. Eur Urol 1989;16:328-32.
Vihko P, Kontturi M, Lukkarinen D. Screening for carcinoma of the prostate: rectal examination, and enzymatic radioimmunologic measurements of serum acid phosphatase compared. Cancer 1985;56:173-7.
von Garrelts B. Analysis of micturition. A new method of recording the voiding of the bladder. Acta Chir Scand 1956;112:326-40.
von Garrelts B. Micturition in the normal male. Acta Chir Scand 1957;114:197-210.
von Garrelts B. Micturition in disorders of the prostate and posterior urethra. Acta Chir Scand 1958;115:227-41.
Vontobel, HP, Herzog R, Rutishauser G, Kres H. Ergelnisse einer doppelblinddstudie ueber die wirksamkeit von ERU kapseln in der kinservativen behandlung der benignen prostatahyperplasie. Urologe [A] 1985;24:49-51. (Ger)[AUTH]+AND+
Wang MC, Valenzuela LA, Murphy GP, Chu TM. Purification of a human prostate specific antigen. Invest Urol 1979-80;17:159-63.
Wasserman NF, Lapointe S, Eckmann DR, Rosel PR. Assessment of prostatism: role of intravenous urography. Radiology 1987;165:831-5.
Wasserman NF, Reddy PK, Zhang G, Berg PA. Experimental treatment of benign prostatic hyperplasia with transurethral balloon dilation of the prostate: preliminary study of 73 humans. Radiology 1990;177:485-94.
Wasson J, Reda D, Bruskewitz RC, Ellison J, Keller A, Henderson WGE. Efficacy and cost of transurethral resection of the prostate for symptomatic benign prostatic hyperplasia. Forthcoming.
Weis KA, Epstein RS, Huse D, Deverka P, Oster G. The costs of prostatectomy for benign prostatic hyperplasia. Prostate 1993;22(4):325-34.
Wennberg JE, Mulley AG Jr, Hanley D, Timothy RP, Fowler FJ Jr, Roos NP, Barry MJ, McPherson K, Greenberg ER, Soule D, et al. An assessment of prostatectomy for benign urinary tract obstruction. Geographic variations and the evaluation of medical care outcomes. JAMA 1988;259:3027-30.
Wilcox RG, Mitchell JRA. Intravenous urography in the management of acute retention. Lancet 1977;1:1247-9.
Windle R, Roberts JBM. Ejaculatory function after prostatectomy. Proc R Soc Med 1974;67:1160-2.
Wolf GL, Arenson RL, Cross AP. A prospective trial of ionic vs. nonionic contrast agents in routine clinical practice: comparison of adverse effects. Am J Roentgenol 1989;152:939-44.
Young JL, Percy CL, Asire AJ, Berg JW, Cusano MM, Gloeckert LA, Horm HW, Lourie WI, Pollack ES, Shambaugh EM. Cancer incidence and mortality in the United States 1973-1977. Natl Cancer Inst Monogr 1981;57:1-1082.
Zohar J, Meiraz D, Maoz B, Durst N. Factors influencing sexual activity after prostatectomy: a prospective study. J Urol 1976;116:332-4.