# Executive Summary

Benign prostatic hyperplasia (BPH), as the most common benign neoplasm in the aging human male, has a high prevalence that increases progressively with age. The prevalence of histologically identifiable BPH for 60-year-old males is greater than 50 percent. By age 85, the prevalence is approximately 90 percent. About one-half of the men with microscopic evidence of BPH will eventually have macroscopic enlargement of the gland (Isaacs, 1990), and approximately one-half of those men will develop clinical symptoms of prostatism.

An estimated one in every four men in the United States will be treated for the relief of symptomatic BPH by age 80 (Barry, 1990, 1991). Over 300,000 surgical procedures for BPH, mostly transurethral resection of the prostate (TURP), are performed annually in the United States (Holtgrewe, Mebust, Dowd, et al., 1989). TURP is the second most common surgical procedure performed in the Medicare population, second only to cataract surgery. The resulting related cost is estimated to be in excess of $2 billion per year (Holtgrewe, Mebust, Dowd, et al., 1989).

BPH is a noncancerous enlargement of the prostate gland. Four conditions are interrelated with the disease process of BPH: (1) anatomic prostatic hyperplasia, (2) the presence of symptoms commonly referred to as prostatism, (3) the urodynamic presence of obstruction, and (4) the response of the bladder (detrusor) muscle to obstruction (Hald, 1989). Some patients have all four conditions and therefore are most likely to have the disease that physicians consider as BPH. Other patients may have anatomic hyperplasia and urodynamic evidence of obstruction without symptoms of prostatism. They are said to have "silent" prostatism.

The dominant risk factors for the development of BPH are increasing age and the presence of androgens. The etiology of the disease remains poorly understood. Long-term outcome data regarding the natural history and treatment of BPH are lacking, and indicators to aid in the proper timing of treatment for BPH are sparse. Because of these uncertainties, there is significant geographic variation in BPH treatment patterns, both among small areas in the United States and among developed countries worldwide.

This guideline is intended to identify the most effective methods for diagnosing BPH and to identify and describe the most appropriate treatments for BPH based on patient preference and clinical need. A central tenet of the recommendations in this document is that the patient should be at the center of the decisionmaking process regarding the diagnosis and treatment of his BPH.

## Diagnosis of BPH

### Initial Evaluation

In the initial evaluation of all patients with prostatism, the following are recommended:

- A detailed medical history focusing on the urinary tract, previous surgical procedures, general health issues, and fitness for possible surgical procedures, in order to identify other causes of voiding dysfunction and comorbidities that may complicate treatment. For some patients, a "voiding diary" may help in determining the frequency and nature of the complaints.
- A physical examination, including a digital rectal examination (DRE) and a focused neurologic examination.
- Urinalysis by dipstick testing or microscopic examination of sediment to rule out urinary tract infection and hematuria.
- Measurement of serum creatinine to assess renal function.

In the initial evaluation, measurement of prostate-specific antigen (PSA) is optional. Testing for PSA increases the detection rate for prostate cancer over DRE alone and may detect the cancer at an earlier stage. However, there is significant overlap in PSA values between BPH and prostate cancer patients. As a result, the PSA test does not discriminate well between patients with symptomatic BPH and those with prostate cancer. Also, there is a lack of consensus regarding the evaluation of minimally elevated PSAs, as many of these tests will be "false positives" in patients symptomatic for BPH. This may lead to unnecessary prostate biopsies. In addition, there is no direct evidence as yet whether the increased diagnosis of prostate cancer through PSA testing will lead to a decrease in morbidity and mortality from the disease.

### Symptom Assessment

The panel believes that quantification of symptom severity is an important step in the evaluation of men with prostatism.

For objective quantification of symptoms, the recommended instrument is the self-administered American Urological Association (AUA) Symptom Index, which consists of seven questions relating to symptoms of prostatism. Some patients need help understanding and completing such questionnaires. The AUA instrument, however, is generally considered easy to administer and score.

In the AUA scoring system, symptoms are classified as mild (0 to 7), moderate (8 to 19), or severe (20 to 35). The AUA symptom score is recommended for use in treatment planning and periodically in followup.

### Additional Diagnostic Tests

Several specific diagnostic tests, discussed below, are available to further assess patients with a presumptive diagnosis of BPH. Data are insufficient to demonstrate the value of these tests for verifying the diagnosis and predicting the results of treatment. Moreover, the optimal thresholds to define normal and abnormal test values are uncertain. Test results thus do not accurately define the severity of BPH. Use of the tests is not mandatory prior to a decision to treat typical patients with a high probability of BPH based on the recommended evaluation. These specific tests, nevertheless, may be valuable if the diagnosis is less certain following the initial evaluation. Other tests may be useful if the patient and physician select more invasive treatment options such as balloon dilation and surgery.

The following tests are optional following the initial evaluation:

- Uroflowmetry is a test that may be useful in patients with symptoms of prostatism because it will identify those whose maximum flowrate is not markedly diminished. These patients are less likely to have bladder outlet obstruction and may respond less well to therapy.
- Pressure-flow studies, while invasive, may be useful in patients whose history and/or examination suggest primary bladder dysfunction (for example, from neurologic disease) as the cause for symptoms of prostatism. Pressure-flow studies may be especially useful in patients for whom a distinction between prostatic obstruction and impaired detrusor contractility might affect the choice of therapy. However, pressure-flow studies may or may not be useful in the workup of the usual patient with symptoms of prostatism.
- Postvoid residual urine (PVR) measurement has not been proven useful in predicting the need for or response to treatment, although patients with large residual urines may have a higher likelihood of failing a watchful waiting treatment strategy. PVR measurements are poorly reproducible for a given patient. However, for patients who elect nonsurgical treatments (including watchful waiting), PVR may be useful in monitoring the course of the disease as PVR measurement may detect worsening obstruction. Repeat measurements should be considered before making treatment decisions based on PVR values. If possible, PVR should be measured noninvasively.
- Urethrocystoscopy is optional during later evaluation if invasive treatment is being planned.

The following tests are not recommended:

- Imaging of the upper urinary tract by ultrasonography or intravenous urography is not recommended for the typical BPH patient. It should be reserved for BPH patients who have concomitant urinary tract disease or abnormalities (for example, hematuria, urinary tract infection, renal insufficiency, previous urinary tract surgery, and history of urinary tract stones).
- Filling cystometry (cystometrography or CMG) is not recommended in the evaluation of typical patients with symptoms of prostatism. It may be useful in the evaluation of patients with suspected neurologic diseases or to determine why individual patients fail to improve after prostate surgery. However, pressure-flow studies are probably a superior alternative in these circumstances.
- Urethrocystoscopy is not recommended as a procedure to determine the need for treatment. Urethrocystoscopy is optional for patients electing invasive therapy (surgery or balloon dilation) in order to assess prostate size and configuration. Urethrocystoscopy may be performed in the office prior to scheduling or in the operating room prior to the procedure. The advantage of the first approach is that the patient can be informed of the results and can participate in the final decision on treatment (for example, surgery as opposed to balloon dilation or transurethral incision of the prostate as opposed to transurethral resection of the prostate). Transabdominal bladder/prostate ultrasonography, but not intravenous urography, can provide the same information on prostate size and configuration noninvasively.

### Treatment of BPH

Asymptomatic patients with prostate enlargement due to BPH rarely require treatment. For those BPH patients who have specific complications due to BPH, such as urinary retention, prostate surgery is usually the most appropriate form of treatment (see Decision Diagram, Attachment A). All other patients should, in consultation with the physician, decide on the treatment after considering the possible outcomes of each potential treatment.

The depth of information desired will vary from patient to patient. To make a treatment decision, the patient needs to consider how "bothered" he is by his symptoms as well as his attitude toward the possible benefits and risks of each treatment option. The health care provider can help guide the patient in making the most appropriate treatment decision.

#### Watchful Waiting

Watchful waiting is an appropriate treatment strategy for the majority of patients. The probability of disease progression or the development of BPH complications without active treatment is uncertain. Until research defines these probabilities, patients following a strategy of watchful waiting should be monitored periodically by reassessment of symptom severity, physical findings, routine laboratory testing, and optional urologic diagnostic procedures.

#### Surgery

Of all treatment options, prostate surgery offers the best chance for symptom improvement. However, surgery also has the highest rates of significant complications. Transurethral resection of the prostate (TURP) is the most commonly used surgical treatment for BPH. Transurethral incision of the prostate (TUIP), a procedure of almost equivalent efficacy, is limited by technical factors to patients in whom the estimated resected tissue weight (if done by TURP) would be 30 grams or less. TUIP can be performed in ambulatory settings or during a 1-day hospitalization. Open prostatectomy is typically performed on patients with very large prostates.

Given proper patient selection, the benefits are probably equivalent for each surgical procedure, but complication rates differ between the procedures. Open prostatectomy, for example, has greater incisional morbidity and a longer recovery time than other procedures. TUIP has the lowest risk of morbidity and the lowest rate of ejaculatory disturbance.

Surgery need not always be a treatment of last resort; that is, patients need not undergo other treatments for BPH before they can have surgery. However, it is inappropriate to recommend surgery for a symptomatic patient on the grounds that progression is inevitable and that surgical risk will only increase with age. BPH progresses slowly and quite variably among patients.

#### Balloon Dilation

Balloon dilation of the prostatic urethra is clearly less effective than surgery in relieving symptoms but is associated with fewer complications. Recent studies suggest that improvement may be temporary, with recurrence of symptoms in most patients within 2 years. At present, balloon dilation is a reasonable treatment option for patients with smaller prostates and no middle lobe enlargement. However, TUIP can be performed in the same patients with superior efficacy, with similar morbidity, and in similar outpatient settings.

#### Alpha Blockers

Alpha-1-adrenergic receptor blockers (such as doxazosin, prazosin, and terazosin) relax bladder neck and prostate smooth muscle. There is no evidence to suggest that any one alpha blocker is more effective than another. As of this writing, the Food and Drug Administration (FDA) has only approved terazosin for use in treating BPH, but doxazosin and prazosin are also commonly used by physicians for this purpose. Titration of dose is necessary. Even with dose titration, patients should respond within weeks to a few months. Although short-term efficacy has been well documented in controlled trials, long-term efficacy is unknown.

Side effects include orthostatic hypotension, dizziness, tiredness, and headache. Up to 11 percent of patients have discontinued therapy in short-term clinical trials because of side effects. The nonselective alpha blocker phenoxybenzamine is not recommended because of a higher incidence of side effects. Also, there is no evidence that alpha blockers reduce BPH complication rates or the need for future surgery.

#### Finasteride

The new drug finasteride was approved in 1992 by the FDA for treatment of BPH. Finasteride is a 5-alpha reductase inhibitor that blocks conversion of testosterone to dihydrotestosterone, the major intraprostatic androgen in men. The drug is taken by mouth once a day. It reduces the size of the prostate, leads to a small average increase in peak urinary flowrate (Qmax), and on average, leads to a small yet perceptible reduction in symptoms. Six months or more of treatment are required for maximal effects. Long-term efficacy is unknown. Side effects are mainly sexually related and include decreased libido, ejaculatory dysfunction, and impotence. During clinical trials, adverse events leading to discontinuation of treatment occurred in approximately 5 percent of the men treated. As with alpha blockers, there is currently no evidence that finasteride reduces BPH complication rates or decreases the need for future surgery.

#### New Technologies

Emerging technologies for treating BPH include lasers, coils, stents, thermal therapy, and hyperthermia. The panel has reviewed the available data regarding these therapies but has found the data insufficient to permit conclusions regarding safety and efficacy of the modalities for routine care. Once controlled clinical trials establish their safety and efficacy, these new technologies will be reviewed during guideline updates. One-year data from randomized, placebo (or sham) controlled trials or randomized comparisons with TURP would be ideal for making such assessments. Established technologies will also be reanalyzed as results of new trials are reported.