# Acknowledgments

The panel wishes to thank Claus G. Roehrborn, MD, for his analytic skill, insight, and hard work, which were crucial to successful completion of the guideline. The previous and ongoing work of the AHCPR-funded Patient Outcomes Research Team (PORT) on BPH and localized prostate cancer, headed by John E. Wennberg, MD, was invaluable, especially the work of Jack Fowler, PhD, in developing the patient preference tests. Special thanks are extended to the staff and Executive Committee of the American Urological Association for its collaboration and cooperation with this project.

Numerous colleagues are also acknowledged for supporting this project. Among the many people who assisted us, we recognize: Steven Woolf, MD, MPH, and Carolyn DiGuiseppi, MD, of the U.S. Preventive Services Task Force; Victor Hasselblad, PhD, of Duke University; and J. Michael McGinnis, MD, of the Office of the Assistant Secretary for Health, U.S. Department of Health and Human Services. The panel is deeply indebted to David Eddy, MD, PhD, who taught us all to "tell it like it is."

Instrumental in facilitating the content reviews needed were Bernard M. Rosof, MD, and Betty King of the Internal Medicine Center to Advance Research and Education; Hanan S. Bell, PhD, of the American Academy of Family Physicians; and Jean Fourcroy, MD, PhD, and Gordon Johnson, MD, of the Food and Drug Administration. We also extend gratitude to the American Medical Review Research Center and specifically thank Thomas C. Fenter, MD, Ruth Ann Hadley, Alison Hardy, and Carole McGoffin.

Curtis Colby and Gary M. Stephenson, MS, provided superb editorial expertise. Robert H. Friedman, MD, Boston University, wrote an early draft of the Quick Reference Guide for Clinicians.Pamela Abbott and Karen Costanzo provided invaluable research support. Special thanks to Lynn McQueen, MS, MPH, RN; Elaine Corrigan, MSp; and William N. LeVee of AHCPR for their help and guidance.