# Panel Members

- John D. McConnell, MD, Chair
- University of Texas Southwestern Medical Center
- Dallas, Texas
- Urologist
- Michael J. Barry, MD
- Harvard Medical School
- Cambridge, Massachusetts
- General Internal Medicine Unit
- Massachusetts General Hospital
- Boston, Massachusetts
- General Internist
- Reginald C. Bruskewitz, MD
- University of Wisconsin Hospital and Clinics
- Madison, Wisconsin
- Urologist
- Anton J. Bueschen, MD
- University of Alabama at Birmingham
- Birmingham, Alabama
- Urologist
- Sherwood E. Denton, MD
- Phoenix, Arizona
- Urologist
- H. Logan Holtgrewe, MD
- Annapolis, Maryland
- Urologist
- John L. Lange, MD
- Holt-Krock Clinic
- Fort Smith, Arkansas
- Urologist
- Bruce L. McClennan, MD, FACR
- Mallinckrodt Institute of Radiology
- St. Louis, Missouri
- Radiologist
- Winston K. Mebust, MD
- Kansas University Surgical Association
- Kansas City, Kansas
- Urologist
- Nancy J. Reilly, MSN, RN, CURN
- University of Pennsylvania
- Philadelphia, Pennsylvania
- Nurse
- Richard G. Roberts, MD, JD
- University of Wisconsin
- Madison, Wisconsin
- Family Physician
- Stephen A. Sacks, MD
- Cedars-Sinai Medical Office Towers
- Los Angeles, California
- Urologist
- John H. Wasson, MD
- Veterans Affairs Hospital
- White River Junction, Vermont
- Dartmouth Medical School
- Hanover, New Hampshire
- Internist