# Dedication

Benign Prostatic Hyperplasia: Diagnosis and Treatment is dedicated to the memory of Sherwood (Woody) E. Denton, MD. A valued member of the BPH Guideline Panel, Woody died while the guideline documents were undergoing editorial review. Always central to his comments during panel meetings was concern for the patient. The patient-centered approach at the heart of this Clinical Practice Guideline to a large extent reflects Woody's contributions to the guideline development process.