# BPH Treatment Summary

## Treatment Options Reviewed

The BPH Guideline Panel collected and reviewed data for commonly utilized, as well as experimental, BPH treatments available at the time. There was adequate evidence in the literature to estimate outcomes for the following treatments:

- Watchful waiting: A strategy of management in which the patient is monitored by his physician, but receives no active intervention for BPH.
- Alpha blocker therapy: Treatment using any of the class of alpha-1-adrenergic receptor blockers (including doxazosin, prazosin, and terazosin) that inhibit alpha-adrenergic mediated contraction of prostatic smooth muscle.
- Finasteride therapy: Treatment using the drug finasteride, an inhibitor of the enzyme 5-alpha reductase, which lowers prostatic dihydrotestosterone levels and can result in some decrease in prostate size.
- Balloon dilation: A procedure for treating BPH in which a catheter with a balloon at the end is inserted through the urethra and into the prostatic urethra. The balloon is then inflated to stretch the urethra where narrowed by the prostate.
- Transurethral incision of the prostate (TUIP): An endoscopic surgical procedure limited to patients with smaller prostates (30 grams or less of resected weight) in which an instrument is passed through the urethra to make one or two cuts in the prostate and prostate capsule, reducing constriction of the urethra. This procedure can be done on an outpatient basis.
- Transurethral resection of the prostate (TURP): Surgical removal of the prostate's inner portion by an endoscopic approach through the urethra, with no external skin incision. This is the most common active treatment for symptomatic BPH and usually requires a hospital stay.
- Open prostatectomy: Surgical removal (enucleation) of the inner portion of the prostate via a suprapubic or retropubic incision in the lower abdominal area. Rarely is the procedure done through the perineum. Open prostatectomy requires a longer hospital stay than do the other surgical procedures.

Treatment modalities such as hyperthermia, thermal therapy, laser prostatectomy, prostatic stents, and hormonal manipulation are considered investigational. With the exception of laser prostatectomy, few of these treatments are available for routine clinical practice. In the case of laser prostatectomy, although it is being utilized in routine practice, the panel found insufficient published data to accept or reject it as a surgical option. As new therapies enter general use and published outcome data become available, they will be reviewed in future updates of this Clinical Practice Guideline. Also, the established treatment options will be reviewed again when new data are available.

## Treatment Recommendations

Based upon the panel's review of treatment options available in clinical practice, as well as on the preferences of patients, the following practice recommendations can be made. (See chapter 1 for definitions of standard, guideline, and option as terms to denote intended degree of flexibility in treatment policies.)

As a standard, patients with mild symptoms of BPH (AUA score>=7) should be followed in a strategy of watchful waiting. The patient's symptoms and clinical course should be monitored, usually annually. He should be instructed on behavioral techniques to reduce symptoms, such as limiting fluid intake after dinner and avoiding decongestants. Probabilities of disease progression or the development of BPH complications are uncertain. Until research defines these probabilities, patients in a strategy of watchful waiting should be monitored periodically by reassessment of symptom level, physical findings, routine laboratory testing, and optional urologic diagnostic procedures. If the patient's symptoms progress to moderate or severe levels, as defined by the AUA Symptom Index, it is appropriate to rediscuss the symptoms with the patient to determine whether the condition is bothersome or is interfering with his health and to offer him other treatment options if applicable.

As a guideline, patients with moderate and severe symptoms (AUA score <=8) should be given information on the benefits and harms of watchful waiting, alpha blocker therapy, finasteride therapy, balloon dilation, and surgery. This information should be presented to the patient in an unbiased format that expresses not only the probabilities of benefits and harms, but the range of uncertainty associated with those probabilities. The physician's opinion about optimal treatment should not be the only information communicated to the patient. The panel recommends use of Treating Your Enlarged Prostate: Patient Guide (available from AHCPR) or other educational materials developed for this problem. However, health care providers should be cautious of using educational materials developed by groups with a vested interest in a particular form of treatment.

If patients initially choose watchful waiting or treatments other than surgery and later experience symptom progression or deterioration, it is appropriate to rediscuss surgery as a treatment option. However, failure to respond to medical or balloon dilation therapy is not an absolute indication for surgery. Many patients who fail to benefit from medical therapy, for example, will elect to return to a strategy of watchful waiting rather than accept the risks of surgery.

On the other hand, surgery should not be "reserved" for those men who fail medical or device therapy. If the patient has been fully informed, it is appropriate for him to have the option of electing surgery as his initial treatment. Choice of type of surgery (TUIP, TURP, or open prostatectomy) is primarily a technical decision; this choice should be based on the surgeon's experience and judgment and should be discussed with the patient. The panel noted, however, that TUIP is an underutilized procedure that should be strongly considered for patients in whom the estimated resected tissue weight (if done by TURP) would be 30 grams or less.

As a guideline, the following types of BPH patients should be treated surgically: (1) those with refractory urinary retention who have failed at least one attempt at catheter removal; (2) those who have recurrent urinary tract infections, recurrent gross hematuria, bladder stones, or renal insufficiency clearly due to BPH. There is little evidence to suggest that treatment options other than surgery benefit patients with any of these BPH complications. Nevertheless, if patients refuse surgery, or if they have sufficient medical comorbidity to present an unacceptable risk for surgery, alternative therapies may be considered.

The intent of the foregoing treatment recommendations is not to diminish the pivotal role of a caring physician in reaching an optimal treatment decision. Rather, it is to expand the physician's counseling role by providing the patient with sufficient information to permit his participation in the decisionmaking process to the extent he desires. In those cases where the patient wishes the physician's opinion on the optional treatment strategy, or even "surrenders" the decision completely to the physician, it is appropriate for the physician to recommend the most optimal treatment and to act as the patient's proxy in the decisionmaking process if necessary. The physician should only take this prerogative, however, at the patient's request.

## Panel Review of Treatment Outcomes

In developing the above recommendations, the panel reviewed the indirect and the direct outcomes for each treatment, as reported in the English-language BPH literature. Indirect outcomes are physiologic end points such as urine flowrate and PVR. They are of most interest to clinicians. Direct outcomes, such as symptom improvement or treatment complications, are of most importance to the patient inasmuch as he experiences them directly in terms of an effect on the quality or quantity of his life.

### Indirect Treatment Outcomes

Peak urinary flowrate (Q[max]) and PVR are the indirect outcomes most commonly used to objectively determine efficacy of BPH treatment in clinical research. All active treatments (alpha blockers, finasteride, balloon dilation, TUIP, TURP, and open surgery) increase Q[max] and decrease PVR; both Q[max ]and PVR respond very little to placebo treatment. The degree of improvement in Q[max] and of reduction in PVR is superior with surgical treatment.

The panel's review (in chapter 8 of this Clinical Practice Guideline) of indirect outcomes reported in the literature, specifically of flowrate and PVR, is intended to provide clinicians with useful information for judging the relative efficacies of treatment options. Until better data are available on use of the parameters to predict the occurrence of BPH complications or response to treatment, these measurements should not be used to influence a patient's decision regarding the appropriateness of a given therapy once a diagnosis has been established.

### Direct Treatment Outcomes

In considering treatment, a patient may not be especially interested in such indirect outcomes as possible improvement of his peak urinary flowrate or decrease of his residual urine, notwithstanding the importance of these parameters to many physicians. The patient is likely to be more interested in such direct outcomes as his degree of symptom improvement after treatment, the chances of complications or side effects of treatment, duration of any hospital stay, and time lost from work, as well as cost. Results of the panel's review of direct outcomes are reported in chapters 9-17 of this Clinical Practice Guideline.

## Panel Analysis of Benefits and Harms

Any therapeutic medical intervention can have both desirable and undesirable outcomes, or benefits and harms (Eddy, 1990b). For determining the appropriateness of individual treatments, as well as developing practice recommendations, the BPH Guideline Panel reviewed in detail the benefits and harms of each treatment option. All outcome evidence for a given treatment option was combined, utilizing the confidence profile method (see chapter 1). Results of this synthesis of the BPH treatment literature are presented in the Balance Sheet Table (Attachment B). In most cases, a 90-percent CI is reported along with the best estimate of the probability. A list of studies reviewed for the combined analysis is presented in Attachment C. Details of the analysis, including its limitations, are discussed in chapters 9-17, which deal specifically with the individual outcomes on the Balance Sheet. (See the Guideline Report for comprehensive analysis.)

The number of outcomes with a wide CI demonstrates that there is considerable uncertainty in the medical knowledge base about BPH treatment. This uncertainty results from either a limited number of studies and patients reported for a given intervention (as is the case particularly for balloon dilation) or from a wide variation in outcome probability reported in different studies (as for alpha blocker therapy). Additional uncertainty results from the short-term duration of many studies in contrast to the long natural history of this chronic condition.

A further limitation is the varying quality of the individual studies. With the exception of short-term medical therapy trials and some studies comparing TURP with TUIP, there are few randomized trials of BPH therapy in the literature. Consequently, much of the data analyzed by the panel came from clinical cases. The methodologic limitations associated with these types of studies are obvious, particularly when results of the studies are compared. Nevertheless, if clinical series were not included in the analysis, little could be said about the possible benefits and harms of surgery or watchful waiting. Data forthcoming in 1994 from a clinical trial by the Veterans Affairs Cooperative Study Group comparing TURP with watchful waiting in 600 patients followed for at least 3 years will add considerably to our knowledge about these 2 treatments.

A particular limitation of the available studies arises from differences in study populations. In many cases, it is likely that patients entered into trials of nonsurgical therapies had less severe disease states than those men undergoing surgery. Also, study durations for alpha blocker and balloon dilation trials were exceptionally short. Thus, the true "failure rates" of these interventions are not apparent from the current evidence. The panel attempted to extrapolate from existing information in order to model long-term failure rates for alpha blocker, balloon dilation, and finasteride therapies. However, this model should be viewed largely as a hypothesis. Durability of response can only be documented in longer term (5-year) clinical trials.

Despite the limitations of the analysis, the panel believes that the broad CIs usually contain the "true" probability of a given outcome. Ultimately, point estimates for outcomes must be determined with more certainty in appropriately designed, randomized trials that compare different therapies in the same population of patients. However, until these types of outcome studies are completed, physicians and patients, who must make decisions in the present, need guidance.

To ensure that the patient has the opportunity to participate actively in this shared decisionmaking process, he must be made aware not only of the best estimates of direct outcomes related to therapy, but also of the range of uncertainty associated with these outcomes.

### Patient Preference Analyses

In choosing treatments for a disease such as BPH, which principally affects the quality rather than the quantity of life and where the optimal decision may be dictated by personal values rather than scientific evidence, different patients may have different opinions concerning the benefits and harms of direct outcomes. Depending on how bothered a patient is by his symptoms, one patient may find the risks of surgery or of other treatments acceptable given the potential benefit. Another patient may not find the risk of any therapy acceptable, because he is not bothered by his symptoms or because he is averse to any risk, or both. These differences in how individual patients weigh risks and benefits are clearly shown in studies of patient preferences.

The panel conducted two types of preference analyses, the results of which are detailed in chapter 18. For the first analysis, nonurologic physicians and PhD-level medical researchers over 60 years old served as "proxy" patients. As their initial task, they were asked to rank direct treatment outcomes in order of importance. They ranked the benefit of symptom improvement as the most important outcome. It was followed by the potential harms of incontinence, medical complications of surgery, operative mortality, complications requiring surgery, and impotence.

The proxies were presented scenarios describing patients with mild, moderate, and severe symptoms of BPH as well as a scenario describing a patient in refractory urinary retention. If they envisioned themselves as having only mild symptoms, the vast majority of proxy patients elected no therapy (watchful waiting). In the moderate symptom scenario, proxy patients demonstrated a wide range of preferences. For severe symptoms or urinary retention, a large majority of proxies predicted they would undergo surgical intervention.

A similar pattern of preferences was observed in the second analysis, which surveyed actual patients with a range of BPH symptoms. Most patients with mild symptoms preferred watchful waiting, whereas there was a very wide range of preferences in patients with moderate symptoms. Although surgery was the most commonly elected therapy for those patients with severe symptoms, a significant number elected watchful waiting or another alternative therapy.

It is clear from these studies that the majority of BPH patients with mild symptoms are not sufficiently bothered by their symptoms to accept the risks of therapy, including noninvasive therapies. In patients with moderate and severe symptoms, there is a wide range of preferences probably due to varying levels of "bothersomeness" and risk aversion among individual patients.

Given the variations in patient preferences, and because the physician's values (personal perceptions of benefits, and harms) may be different from the patient's, it is important that the patient's values take precedence in determining choice of treatment. Although patients with severe symptoms are more likely to be bothered, and thus will be more likely to accept the risk of surgery, a considerable number of these patients will still prefer watchful waiting or other therapies.

It is also apparent that the "need" for therapy in patients with symptomatic BPH should, in most cases, be determined by the informed patient rather than by the physician. As made evident above, most patients with mild symptoms do not perceive a need for therapy even with noninvasive approaches. Patients with severe symptoms may choose surgery, but many will have a preference for nonsurgical intervention.

However, an appreciable number of patients with moderate symptoms, after being fully informed, will also elect surgical intervention. Therefore, the concept that patients should only receive surgery if they have failed medical therapy is not appropriate. Some patients with moderate symptoms, and significantly bothered by their symptoms, view the potential benefits of surgery as clearly superior to other forms of therapy and the risks as acceptable.

### Analysis of Treatment Options

After an exhaustive review of the benefits and harms for each treatment option, the panel incorporated the results of the patient preference analyses into the guideline development process to help determine the net benefit (or value) of a given treatment modality. The panel concluded that, based on current evidence and its limitations, the following are all appropriate options to offer the moderately or severely symptomatic patient: watchful waiting, alpha blocker therapy, finasteride therapy, balloon dilation, and surgery.

#### Alpha Blockers.

Alpha blockers (doxazosin, prazosin, and terazosin), approved by the FDA for use in treating hypertension, are also widely used by physicians for treatment of BPH. The FDA has approved terazosin to treat BPH. Other alpha blockers are currently under FDA review. Doxazosin and terazosin are given once a day, usually at bed time, and prazosin is given twice daily. The panel's combined analysis demonstrates a benefit of alpha blockers in reduction of symptoms and increase in uroflow. The pivotal trial that led to the approval of terazosin for treatment of BPH was not included in the combined analysis (Lepor, Auerbach, Puras-Baez, et al., 1992). However, the panel's subsequent review of these data found the benefits of treatment to be very similar to those seen in combined analysis.

The major limitation of alpha blocker therapy is its uncertain long-term effectiveness. The longest controlled studies of alpha blockers in the literature are 6 months in duration. It is unclear whether ongoing growth of the prostate or tachyphylaxis will result in deterioration of symptom improvement over time. The primary side effects are orthostatic hypotension, dizziness, tiredness, and nasal congestion. There is no evidence that alpha blockers reduce BPH complication rates or the need for future surgery. Nevertheless, alpha blocker therapy is efficacious in the short term and warrants consideration as a treatment option.

#### Finasteride.

A new drug, finasteride, has been approved by the FDA for the treatment of BPH. It can reduce the size of the prostate, increase peak urinary flowrate, and reduce BPH symptoms in some men (Gormley, Stoner, Bruskewitz, et al., 1992). Side effects are primarily sexually related and include decreased libido, ejaculatory dysfunction, and impotence. As with alpha blockers, there is no evidence that finasteride reduces BPH complication rates or the need for future surgery. Because it is a new treatment, finasteride's long-term benefits and risks are not known. However, it is appropriate to consider finasteride as a treatment option.

#### Balloon Dilation.

Balloon dilation has been inadequately studied, especially in controlled long-term outcome trials. A number of balloon dilation catheters have been approved by the FDA for the treatment of BPH. Short-term studies were enthusiastic. However, longer followup studies demonstrated a significant failure rate. One controlled trial performed suggests minimal improvement compared with cystoscopy (Lepor, Sypherd, Machi, et al., 1992), but this study was not definitive because of the small number of patients studied and the resultant broad CIs around the efficacy estimates. Another small controlled trial comparing balloon dilation with TURP suggested similar efficacy initially, but a decline in improvement in the dilation arm after 1 year (Donatucci, Donohue, Berger, et al., 1993).

Given the safety of balloon dilation, the panel considers it an appropriate option at present. Yet TUIP has a similarly low level of morbidity and an efficacy clearly superior to dilation, and can be performed on an outpatient basis. If longer term studies confirm preliminary observations that the effect of balloon dilation deteriorates with time, it may be reconsidered as an option in future versions of this Clinical Practice Guideline. To recommend against it at this time would be premature. Nevertheless, the approval of balloon dilation initially is questionable given the limited evidence in the literature of its efficacy.

#### Surgery.

The comparison of surgical options (TUIP, TURP, open prostatectomy) suggests that open prostatectomy is slightly more effective than TURP and that TURP is slightly more effective than TUIP. However, there have been no adequately controlled trials conducted on open prostatectomy, and several randomized trials comparing TUIP with TURP suggest little difference in long-term outcomes.

The panel believes that the justification for performing one surgical procedure rather than another should be based mainly on the size and shape of the gland itself. This is largely a question of surgical judgment -- not patient preference. In fact, even the physician proxy judges in the patient preference analysis could not adequately distinguish between the benefits and harms of the three surgical options when they were formally presented in a balance sheet. Therefore, if the patient elects a surgical intervention, or if it is recommended because of acute urinary retention (or other indications for surgery), the choice of surgical approach should be left primarily to the surgeon. The panel does believe that TUIP is an underutilized procedure. Its long-term effectiveness in glands with less than 30 grams of resectable tissue weight (estimated by DRE) is approximately equivalent to TURP, with less cost and morbidity. This option should be considered in all appropriate cases.

Attachment C lists the studies from the treatment literature that the panel reviewed for combined analyses of treatment outcomes. Studies reviewed for the combined analyses are listed in Attachment C by type of treatment. In most cases, these studies are not cited individually in the text discussion. Several studies published after completion of the panel's combined analyses were nevertheless reviewed by the panel and referenced in the discussion.