# Tests Not Recommended

## Filling Cystometry (Cystometrography or CMG)

Filling cystometry adds limited information to the evaluation of most men with prostatism and is not recommended in routine cases. The test may have value in the evaluation of patients with known or suspected neurologic lesions and prostatism, but pressure-flow studies provide more specific information. In patients with suspected primary bladder or neurologic lesions and who cannot urinate (retention), filling cystometry may be useful.

Filling cystometry, an invasive urodynamic study, provides information on bladder capacity, the presence and threshold of uninhibited detrusor contractions (UDCs), and bladder compliance. UDCs are present in about 60 percent of men with prostatism and correlate strongly with irritative voiding symptoms. Compliance is a measure of the elasticity and distensibility of the bladder wall and is expressed as the ratio of volume to pressure (mL/cm).

### Test Performance Methods

The International Continence Society (ICS) has established performance criteria for filling cystometry. In general, sterile fluid should be instilled into the bladder with continuous measurement of the intravesical pressure. The bladder should be filled at a moderate rate between 10 and 100 mL per minute. The fluid should be warmed to body temperature except when performing a provocation test (ice water test) with cold fluid.

The patient's response is monitored during filling, especially for urinary urgency sensations such as first sensation of filling, strong sensation, urge to urinate, or uncontrollable urge to urinate. The test is stopped when the patient has a strong urge to urinate. Usually it is performed with the patient in a supine and relaxed position, but he may also be in an upright or sitting position. If there is uncertainty about the presence or absence of UDCs, the examination might be repeated as a provocation test by fast-filling, filling with cold fluid, or filling with the patient in an upright position.

To obtain reliable results, a fluid-inflatable balloon is inserted into the patient's rectum during cystometry to record the intrarectal pressure as a proxy for the intra-abdominal pressure. The difference between the intravesical pressure (P[ves]) and the intra-abdominal pressure (P[abd]) represents the true detrusor pressure (P[det]) measured in centimeters H[sub2]O (P[ves] - P[abd] = P[det]).

Definitions for normal cystometric values have been published in four reports of the ICS (Abrams, Blaivas, Stanton, et al., 1988). Involuntary pressure increases that are greater than 15 cm H[sub2]O above baseline are considered UDCs.

### Correlation of UDCs and Irritative Voiding Symptoms

Irritative voiding symptoms, common in men with BPH, are correlated with the presence of UDCs. The high incidence of UDCs in patients evaluated for BPH is well documented. The probability of preoperative UDCs does not differ much among the studies. Analysis of the published data reveals a mean probability of 60.2 percent of preoperative UDCs. This finding is associated with a 90-percent CI ranging from 52 to 68 percent.

From data in three studies reporting the postoperative prevalence of UDCs (Abrams, Farrar, Turner-Warwick, et al., 1979 ; Jensen, Bruskewitz, Iversen, et al., 1984 ; Kadow, Feneley, and Abrams, 1988), the overall mean probability of having UDCs after prostate surgery was calculated at 26 percent with a 90-percent CI ranging from 17 to 39 percent. The data indicate that surgery significantly reduces the prevalence of the problem.

The persistence of postoperative UDCs correlates with persistent symptomatology, and thus treatment failure (McLoughlin, Gill, Abel, et al., 1990). However, the finding of preoperative UDCs is not predictive of persistent posttreatment UDCs.

In practice settings where pressure-flow studies are not available, filling cystometry may give some information on bladder function in patients suspected of having a primary or neurogenic bladder disease. However, the value of the test is inferior to pressure-flow urodynamic evaluation.

### Conclusions

UDCs are more common in men evaluated for prostatism than in randomly selected, age-matched controls. This urodynamic finding correlates significantly with the presence of irritative symptoms. Filling cystometry does not add significant new information to the evaluation of men with prostatism. UDCs resolve in most patients after surgery. Only about one-fourth of patients who have UDCs before treatment retain them afterward. Patients whose symptoms do not improve following surgery are more likely to have persistent UDCs.

Although filling cystometry may demonstrate a poorly contractile detrusor in men with primary bladder dysfunction, pressure-flow studies provide much more insight into the interaction between bladder contraction and urethral resistance. Filling cystometry may be considered for men in urinary retention who cannot urinate for a pressure-flow study.

## Urethrocystoscopy

Urethrocystoscopy is not recommended to determine the need for treatment. The test is recommended for men with prostatism who have a history of microscopic or gross hematuria, urethral stricture disease (or risk factors, such as history of urethritis or urethral injury), bladder cancer, or prior lower urinary tract surgery (especially prior TURP). To help the surgeon determine the most appropriate technical approach, urethrocystoscopy is an optional test in men with moderate- to-severe symptoms who have chosen (or require) surgical or other invasive therapy.

Endoscopy of the lower urinary tract (urethrocystoscopy) provides visual documentation of the appearance of the prostatic urethra and bladder in men with BPH. Historically, many urologists believed that the visual appearance of the lower urinary tract defines the severity of disease or predicts the outcome of treatment. However, this common urologic procedure has been poorly studied. No data are available on the sensitivity, specificity, or predictive value of the test.

Urethrocystoscopy is associated with certain potential benefits and harms (although they are not quantified in the literature). Potential benefits include the ability to demonstrate prostatic enlargement and visual obstruction of the urethra and the bladder neck; identification of specific anatomic abnormalities that alter clinical decisionmaking; identification of bladder stones, trabeculation, cellules, and diverticula; measurement of PVR; and the ruling out of unrelated bladder and urethral pathology. Potential harms include patient discomfort, anesthetic or sedative risk, urinary tract infection, bleeding, and urinary retention.

The probability of any of these harms occurring is uncertain. Except for discomfort, their occurrence is likely to be infrequent. Nevertheless, potential harms must be balanced against potential benefits of this invasive procedure.

### Instrumentation

Urethrocystoscopy can be performed with rigid or flexible instruments. Standard rigid instruments provide clearer visualization, a better field of view, and a larger working channel. As an alternative to rigid instruments, flexible cystoscopes have been developed. Flexible cystoscopy has distinct advantages. The instruments are smaller in diameter and therefore more convenient and more comfortable for the examination of male patients. Flexible urethrocystoscopy can be performed easily as an outpatient procedure in the physician's office.

### Correlation with Other Parameters

Simonsen, Moller-Madsen, Dorflinger, et al. (1987) prospectively evaluated 199 BPH patients who underwent prostatectomy. A statistically significant correlation (p <0.05) was found between objective findings (including length of the prostatic urethra, and estimated weight of the prostate gland) and the irritative symptoms as indicated by the patient. Cystoscopic appearance of the prostate and bladder, however, did not correlate with obstructive symptoms.

Andersen and Nordling (1980) investigated the correlation between endoscopic and urodynamic findings in a group of 93 patients with prostatism. The investigators found that prostatic weight (estimated by rectal examination, and by urethrocystoscopy) and the bladder neck to verumontanum distance correlated significantly with the opening pressure, and that the cystoscopically estimated weight and the bladder neck to verumontanum distance also correlated with the maximum flowrate. However, the cystoscopic findings were not related to PVR or detrusor instability. More important, the presence of "cystoscopic obstruction" (occlusion) did not correlate with Q[max] or PVR.

### Bladder Trabeculation, Cellule, and Diverticula Formation

Urethrocystoscopy can identify the presence of lower urinary tract complications that may be due to BPH (for example, bladder diverticula) or may mimic the symptoms (for example, urethral stricture disease). The low probability of these findings in men without hematuria, urinary tract infection, or a history of risk factors makes it difficult to justify the procedure for routine evaluation of all men with prostatism.

If the patient has a finding indicative of possible bladder stones (for example, hematuria or recurrent infection), then urethrocystoscopy is indicated. A history of urethritis or prior urethral injury increases the risk of stricture disease and also makes urethrocystoscopy an appropriate consideration.

Remarkably, few studies address correlations between bladder trabeculation symptoms, urodynamics, and the outcome of surgery. Bladder trabeculation may predict a slightly higher probability of failing a watchful waiting management strategy. No report in the literature correlates cellule or diverticula formation with symptomatology or outcome after surgery.

The detection of bladder diverticula may be of therapeutic relevance. For example, the presence of a large bladder diverticulum may influence the type of surgical intervention (open as opposed to closed prostatectomy). However, no data are available to document the sensitivity or specificity of cystoscopy, cystography, intravenous urography, or transabdominal ultrasonography in the evaluation of patients for such diverticula. Moreover, data on the natural history of untreated as opposed to treated diverticula are not available.

### Predictive Value

The endoscopic appearance of the bladder and prostate is often felt to be helpful in the decision to treat. Although the linkage between the endoscopic appearance of the lower urinary tract and treatment outcome is poorly documented in the literature, available information suggests that the relationship is minimal. Bladder trabeculation may predict a slightly higher failure rate in patients managed by watchful waiting but does not predict the success or failure of surgery. Urethrocystoscopy may, nevertheless, be useful in determining the technical feasibility of specific invasive therapies. For example, if urethrocystoscopy reveals a large middle lobe, balloon dilation and transurethral incision of the prostate (TUIP) are unlikely to be successful. The decision to perform an open prostatectomy may be appropriately influenced by the shape of the gland, as well as its size. In all of these cases, however, the patient and his physician have already selected invasive therapy. Urethrocystoscopy is therefore performed to select (or rule out) specific techniques, not to determine the need for treatment.

### Conclusions

The remote probability of identifying, by urethrocystoscopy, lower urinary tract complications possibly due to BPH, in men without hematuria, urinary tract infection, or a history of risk factors, makes the routine use of this procedure for all men with prostatism questionable. Available data suggest there is a minimal relationship between the endoscopic appearance of the lower urinary tract and treatment outcome. However, urethrocystoscopy may be useful in determining the technical feasibility of specific invasive therapies.

## Imaging of the Urinary Tract

Upper urinary tract imaging is not recommended in the routine evaluation of men with prostatism unless they also have one or more of the following: hematuria; urinary tract infection; renal insufficiency (ultrasound recommended); history of urolithiasis; history of urinary tract surgery.

Intravenous urography (IVU), to image the urinary tract of men with BPH prior to treatment, is performed by 73.4 percent of urologists in the United States (Holtgrewe, Mebust, Dowd, et al., 1989). The number of urologists using ultrasonography to image the urinary tract is unknown. IVU is associated with a 0.1-percent incidence of significant adverse events. There are no direct adverse events known to be associated with ultrasonography.

Of all imaging studies performed in men with BPH, 70 to 75 percent are entirely normal. Only a small fraction of the 25 to 30 percent of abnormal findings mandate changes in the management of the patient. The incidence of any significant findings is no higher in the urinary tract of men with BPH, compared with age- and sex-matched controls, except for bladder stones, diverticula, and trabeculation indicating the presence of bladder outlet obstruction.

A decision to restrict upper urinary tract imaging to patients with hematuria, urinary tract infection, renal insufficiency, a history of urolithiasis, and a history of urinary tract surgery could result in an improved diagnostic yield and reduce cost without jeopardizing quality of care.

### Background

Imaging of the urinary tract prior to prostate surgery has become an integral part of the urologic workup of patients with benign prostatic obstruction.

The frequently made decision to image the urinary tract prior to prostatectomy has been questioned by several authors (Butler, Donnelly, and Komaranchat, 1978 ; Bauer, Garrison, and McRoberts, 1980 ; Christofferson, and Moller, 1981 ; Wasserman, Lapointe, Eckmann, et al., 1987). They each base their recommendation to eliminate imaging, as a routine policy, on their analyses of series of patients with BPH.

Other authors recommend an alternative imaging modality to IVU, namely ultrasonography, to evaluate the urinary tract (Lilienfeld, Berman, Khedkar, et al., 1985 ; Cascione, Bartone, and Hussain, 1987 ; Solomon, and Van Niekerk, 1988 ; Stavropoulos, Christodoulou, Chamilos, et al., 1988). Their recommendation is based on the superiority of sonography in assessing renal lesions seen on intravenous urography and on its harmlessness and noninvasiveness.

Nevertheless, other investigators continue to maintain that routine IVU imaging should remain part of the perioperative workup of BPH patients, and they present data on screened patient populations to support their views (Donker, and Kakiailatu, 1978 ; Pinck, Corrigan, and Jasper, 1980 ; Muzafer, 1986).

### Summary of Health Outcomes

One often stated benefit of evaluating the urinary tract prior to BPH treatment is the opportunity to locate lesions in the kidney, such as stones or tumors, that would otherwise have gone undetected. Additional benefits include identification of hydronephrosis, large residual urine, or diverticula that may affect management.

Another stated benefit of a pretreatment imaging policy may be reduction in unnecessary or untimely prostate surgeries. If prostate size is accurately assessed, the risk of undergoing a type of surgery not indicated for a given gland size (TURP as opposed to open prostatectomy) might be reduced. This could affect duration of hospital stay, time of recovery, and cost of care.

Harms associated with a pretreatment evaluation policy include the cost of the procedure, the time spent by the patient away from work, biologic effects (such as radiation effects), risk of allergic or other nonlethal adverse effects due to the contrast medium, and the slight risk of dying from an adverse reaction to the contrast material.

### Contrast Media Risk

Several large-scale studies were reviewed to determine the incidence of adverse effects due to the use of contrast media Table 11 Adverse effects can be classified in ascending order of severity as (1) mild or minimal (self-limited, physiologic, and transient); (2) moderate or intermediate (transient, not life threatening, but may need treatment); (3) severe (life threatening, with treatment, and/or hospitalization required); and (4) death. If the adverse effects are listed in a study according to these categories, Table 11 presents them as such. If no information is given in the study as to the exact nature of adverse effects, the table entry is in the category "Any adverse effects."

Table 11. Adverse effects due to intravenous administration of contrast

Source of study | Type of contrast medium | N1 | Minor adverse effects[2] | Major adverse effects[3] | Any adverse effects[4] | Death[5]
J Radiol Electrol 1966;47:346 | Ionic | 912,300 | | | 0.00164%
Invest Radiol 1970;5:374 | Ionic | 318,500 | | 5.000% | 0.00251%
Am J Roentgenol 1973;119:832 | Ionic | 33,000 | | | 0.00303%
Am J Roentgenol 1975;124:145 | Ionic | 81,278 | | | 0.00738%
Am J Roentgenol 1982;139:919 | Ionic | 300,000 | | | 0.00133%
N Engl J Med 1987;317:845 | Ionic | 6,763 | | 0.399% | 7.497% | 0.00000%
Am J Roentgenol 1989;152:939[6] | Ionic | 6,006 | 2.531% | 1.582% | 4.113% | 0.00000%
Radiology 1990;175:621[7] | Ionic | 169,284 | | 0.254% | 12.658% | 0.00059%
Am J Roentgenol 1989;152:939[8] | Nonionic | 7,170 | 0.586% | 0.112% | 0.697% | 0.00000%
Radiology 1990;175:621[9] | Nonionic | 168,363 | 0.045% | 3.134% | 0.00059%
Australas Radiol 1988;32:426[9] | Nonionic | 30,268 | 0.02% | | 0.00000%
Total ionic contrast media: | | 1,827,131 | 2.531% | 0.303% | 7.613% | 0.00192%
Total nonionic contrast media: | | 205,801 | 0.586% | 0.044% | 3.034% | 0.00048%
1. Number of patients in study.; 2. Minor adverse effects noted (if specified as minor).; 3. Major adverse effects noted (if specified as major).; 4. Any adverse effects noted (if adverse effects do not fallin specified category).; 5. Death reported in connection with administration of contrast medium.; 6. Prospective randomized trial.; 7. Prospective randomized trial from the Japanese Committee on the Safety of Contrast Media.; 8. Causal relationship to administration of contrast material not established.; 9. Only patients receiving low osmolar contrast media considered.

Those studies describing the use of high osmolar (ionic) contrast media (HOCM) are generally older than those using low osmolar (nonionic) contrast media (LOCM). In general, the weighted incidences for both minor (mild or minimal) and major (moderate to severe) adverse effects are 5-10 times lower for LOCM than for HOCM. The incidence of "Any adverse effects," as defined in Table 11, is about twice as high for HOCM as for LOCM. The death rate following the intravenous administration of HOCM is about 2 in 100,000 (0.0019 percent), compared with 0.48 in 100,000 (0.00048 percent) following LOCM. However, the mortality rates following HOCM are based in part on a study from 1966 in which 15 of 912,300 patients died and on another report from 1982 in which 4 of 300,000 patients died. All of the patients who died had histories of hypersensitivity to other drugs.

Two randomized trials are available to directly compare adverse effects resulting from intravenous administration of HOCM or LOCM in similar populations: (1) Wolf, Arenson, and Cross (1989) and (2) Katayama, Yamaguchi, Kozuka, et al. (1990), the second by the Japanese Committee on the Safety of Contrast Media (JCSCM).

In the JCSCM report, the relative risk of experiencing major adverse effects for patients receiving HOCM was 5.6, with a 95-percent CI ranging from 4.4 to 7.2 percent. In the Wolf study, this relative risk was 14.2 (95-percent CI 6.9-29.1 percent). A combined analysis of both reports yielded a relative risk of 6.2 (95-percent CI 4.9-7.8 percent). In the JCSCM report, the odds ratio for severe and very severe adverse effects was 0.19 and 0.10, respectively, in favor of LOCM. In the Wolf report, the difference between the incidences was significant at a level of p <0.005 for both moderate and severe adverse effects in favor of LOCM.

Kinnison, Powe, and Steinberg (1989) reviewed 100 randomized controlled trials conducted in humans to compare the safety and efficacy of LOCM as opposed to HOCM. In the 43 trials judged most superior, imaging with LOCM was equal to or of better quality than imaging with HOCM for all applications. No differences were seen in regard to mild adverse effects such as nausea, vomiting, and urticaria. More important, greater cardiovascular changes occurred with the use of HOCM, while nephrotoxicity was the same for both types of media. This is consistent with data from Schwab, Hlatky, Pieper, et al. (1989), who found no difference in nephrotoxicity between LOCM and HOCM in 443 patients undergoing cardiac catheterization.

Despite clear evidence of a better safety profile for LOCM, the universal use of low osmolar contrast media is limited by their substantially higher cost. Powe, Steinberg, Erickson, et al. (1988) revealed that average costs for the hospital of managing mild, moderate, and severe adverse effects were $2.52+/-5.33, $24+/-54, and $910+/-749, respectively. On the other hand, the average difference in material costs ranged from $93 (body computerized tomographic [CT] scan) to $179 (cardiac catheterization), thus making the routine use of LOCM not cost-effective. Patients at risk (over 50 years of age, debilitation, severe cardiovascular disease, severe allergy or asthma, prior reaction to contrast media) should, however, receive the benefit of the lower-risk LOCM (McClennan, 1990).

The data in Table 11 indicate that, for a patient undergoing intravenous administration of contrast media, the probability is <= 0.3 percent for having a significant adverse event and about 5 percent for having any or mild adverse effects. The likelihood of death resulting from the test is probably less than 1 to 2 per 100,000 examinations.

### Prostate Size Estimates

To evaluate the accuracy of various imaging modalities in assessing size and thereby weight of the prostate gland prior to surgery, the panel reviewed a large number of studies using IVU, transabdominal and transrectal ultrasonography, digital rectal examination, and urethrocystoscopy. Findings demonstrate that ultrasonographic (transabdominal, and transrectal) methods allow the most accurate estimation of the prostate size (r = 0.88 and 0.89). If knowledge of the exact prostate size is important prior to a planned procedure, an ultrasonographic evaluation policy is better than an IVU policy (r = 0.195). It is noteworthy that digital rectal examination shows a better correlation with the actual resected weight (r = 0.445) than IVU-based estimation. Urethrocystoscopy is less accurate than either transabdominal or transrectal ultrasonography (r = 0.615).

### Upper Tract Findings

To evaluate the rate of unexpected and significant findings anticipated from a screening policy, the panel analyzed 25 studies using intravenous urography (n = 6,131) and 9 studies using ultrasonography (n = 778) to evaluate the upper urinary tract in patients with BPH (Table 12). The nine ultrasonography studies represent a direct comparison between IVU and ultrasonography done on the same patients. The mean age in both of these populations was identical (68.4 years).

Table 12. Incidence of significant findings in series using IVU and US in men with BPH, two series using IVU for other indications, and two series using KUBs in an unscreened population

Designations and types of findings | IVU for BPH[1] | US for BPH[1] | IVU for other indications[1] | KUB in unselected patients[1]
Number of studies | 25 | 9 | 2 | 2
Number of patients | 6,131 | 778[2] | 10,558 | 1,000
Mean age | 68.4 | 68.4 | N/A | N/A
Normal studies | 77.5 | 68.3 | 70.4 | 70.5
Uni- or bilateral hydronephrosis | 5.8 | 6.9 | 3.8 | 0.6[3]
Percentage of patients with hydronephrosis who had renal insufficiency | 33.3 | 23.3 | N/A | N/A
Poorly functioning kidneys | 8.3 | N/A | N/A | N/A
Poor image quality | N/A | 7.5 | N/A | N/A
Renal mass requiring evaluation noted | 1.7 | N/A | 3.1 | N/A
Renal cyst diagnosed | 4.5 | 15.0 | N/A | N/A
Solid renal tumors diagnosed | 0.44 | 0.51 | 0.18 | N/A
Renal stones | 2.1 | 1.3 | 11.0 | 2.8
Ureteral stones | 0.5 | 0 | 2.1 | 0.9
Bladder stones | 2.7 | 3.2 | 0.2 | 0.1
Bladder diverticula | 3.4 | 3.2 | 0.3 | N/A
Bladder trabeculation | 32.1 | 33.7 | 0.3 | N/A
Ureteropelvic junction obstruction | 0.41 | 1.3 | 0.45 | N/A
Nonfunctioning kidney | 0.38 | N/A | 1.4 | N/A
Solitary kidney | 0.59 | 1.89 | N/A | N/A
Ectopia | 0.77 | 0.99 | 0.18 | N/A
Horseshoe kidney | 0.44 | 0 | 0.23 | N/A
Chronic pyelonephritis | 1.28 | 2.27 | 2.43 | N/A
Renal scars | 1.8 | 0.5 | N/A | N/A
Size difference between kidneys | 1.43 | 1.0 | 4.8[4] | N/A
Gallstones | 1.38 | 2.19 | N/A | 2.6
Abdominal aortic aneurysm | 0.75 | 0.88 | N/A | 1.2

1. Incidence in percent unless otherwise specified.

2. All 778 patients were also examined by IVU and are included in the 6,131 patients.

3. Presumably based on the presence of large renal shadow on KUB.

4. Reflects unilateral renovascular hypertension, 27/558 patients screened with hypertension.

Note: IVU = Intravenous urography, US = Ultrasound, KUB = Kidney-ureter-abdominal radiograph, N/A = Not available.

To place the results obtained in a broader context, four other studies were also analyzed. Two of these studies describe the findings in a large number of patients undergoing IVUs for various reasons other than BPH. Leary, Myers, Greene, et al. (1972) studied 558 hypertensive patients by IVU. Ochsner, Buchtel, and Little (1965) reported the findings in 10,000 patients who underwent IVU within a 5-year period at the Ochsner Clinic. Two reports detail the findings from 500 KUBs (kidney-ureter-bladder abdominal radiographs) obtained on patients admitted for chest diseases (Nishio, Kass, and Levine, 1962) and on a series of 500 patients over 40 years of age (268 male, 232 female) seen as either outpatients or inpatients at a university hospital (Rosenbaum, Lieber, Hanson, et al., 1964).

As shown in Table 12, of all IVUs performed in patients with BPH, 77.5 percent were entirely normal (weighted average). Of all ultrasonography evaluations, 68.3 percent were normal. In the two series of IVUs done for indications other than BPH, 70.4 percent of the imaging studies were interpreted as normal; and 70.5 percent of the KUBs were normal.

Only in 22.5 to 31.7 percent of all patients with BPH were any significant findings identified, which is almost identical to findings in the population that had IVUs done for indications other than BPH (29.6 percent). The percentage of normal imaging studies did not differ in reports in which certain patients were excluded because of conditions such as renal failure, urinary retention, hematuria, and urinary tract infection. In fact, in two reports in which all patients were in urinary retention (Marshall, Singh, and Blandy, 1974 ; Butler, Donnelly, and Komaranchat, 1978), the percentage of normal studies was higher than average (86.6 percent, and 81.3 percent, respectively). Only two reports indicated the number of patients who had some degree of renal insufficiency (Donker, and Kakiailatu, 1978 ; Bauer, Garrison, and McRoberts, 1980). Overall incidence was 12.7 percent (116 of 908).

The incidence of some degree of uni- or bilateral hydronephrosis from these combined studies was 5.8 percent for IVU and 6.9 percent for ultrasonography (weighted averages). In the studies done for indications other than BPH, hydronephrosis was found in only 3.8 percent of patients. It was identified on the KUB in 0.6 percent of patients in the KUB series, presumably by an enlarged kidney shadow. Those series with a 100-percent rate of urinary retention did not have the highest incidence of hydronephrosis (3.0 percent, and 12.3 percent) as compared with all series (range from 0 to 40 percent).

Renal insufficiency in patients with BPH carries a higher surgical morbidity and mortality, but the correlation has not been established for the presence of hydronephrosis without renal insufficiency. Thus, it is important to determine the percentage of patients with hydronephrosis who had renal insufficiency. In the IVU series 33.3 percent, and in the ultrasonography series 23.3 percent, of patients with hydronephrosis had renal insufficiency as defined by the investigators. In these patients, assessment of the presence of hydronephrosis was important because it indicated a higher risk category. However, the two-thirds majority of patients with only hydronephrosis did not measurably benefit from the imaging study.

In 1.7 percent (66 of 3,880) of IVUs, a renal "mass lesion" was suspected, requiring further evaluation by ultrasonography or CT scanning. The incidence of "renal cysts" by IVU was 4.5 percent (232 of 5,111). Ultrasonography detected benign renal cysts in 15.0 percent of BPH cases (117 of 778), and these patients did not require confirmational studies. Assuming that most patients found by IVU to have a "mass lesion" or a "renal cyst" will undergo another confirmational imaging study, approximately 6.2 percent of all patients screened would require such testing at a cost of between $300 (for ultrasonography) and $500 to $800 (for CT scanning).

However, kidneys were poorly visualized by ultrasonography in 7.5 percent of the reported cases. Although this percentage was only mentioned in one study, it can be assumed that a sizable number of patients with suboptimal ultrasonography examinations will require another imaging modality, presumably IVU or CT scanning. These are indirect costs associated with a screening policy employing either IVU or ultrasonography.

Table 12 shows that, for BPH patients, 0.44 percent of renal tumors were detected by IVU and 0.51 percent detected by ultrasonography. These calculations are based on several assumptions; for the IVU series, only cases labeled as solid renal tumors were counted. For the ultrasonography series, it was assumed that no solid tumor was found if there was no specific mentioning of solid renal tumors. The rationale for this assumption was that if cystic renal lesions were detected by ultrasound in a certain percentage of patients, the presence of a solid renal lesion would probably have been mentioned. The purpose of the reports was to find evidence for or against the use of imaging modalities in BPH patients based on significant lesions found.

The incidence of renal cancer in the United States is approximately 20-50 per 100,000 in the male population between the ages of 60 and 70 (Young, Percy, Asire, et al., 1981). The autopsy prevalence of renal cell carcinoma has been found to range from 0.18 to 0.30 percent (Harvey, 1947 ; Bell, 1950 ; Lucke, and Schlumberger, 1957).

A retrospective study of 558 hypertensive patients (Leary, Myers, Greene, et al., 1972) reports a prevalence of renal cell cancer of 0.18 percent (1 of 558). This study included men and women of different age groups, populations with a lower incidence of renal cancer than that in men between the ages of 60 and 70. Thus, it appears unlikely that the prevalence of renal cell carcinoma in the BPH population is higher than in age- and sex-matched controls. Screening for renal tumors is not justified when based on the assumption of an increased incidence of tumors in patients with BPH.

### Bladder Stones

The incidence of bladder stones, Table 12 shows, was 2.7 percent in the IVU series (BPH) and 3.2 percent in the ultrasonography series. It was much lower in the series done for indications other than BPH (0.2 percent) and in the KUB series (0.1 percent). This reflects the fact that patients with BPH have outflow obstruction and presumably residual urine, which predisposes them to bladder stone formation. Bladder stones in general do not alter the planned surgical approach in treatment of BPH. If they exceed a certain size, an open procedure may be contemplated. Because no size information is given, no statement can be made about the value of these findings.

For the same pathophysiologic reasons, Table 12 shows that the incidence of bladder diverticula varied greatly between the IVU and ultrasonography series and the "other indications" and KUB series. Even more pronounced were the differences between the IVU and ultrasonography series and the "other indications" series concerning presence of bladder trabeculation. However, the value of these findings is questionable because only rarely do they alter the treatment approach in patients with BPH, and their impact on surgical outcome is unknown.

### Conclusions

About 70 to 75 percent of all imaging studies obtained in patients with BPH are entirely normal, and only a small fraction of the findings obtained in the remaining 25 to 30 percent actually require active intervention or a change in the approach to the patient. Bundrick and Katz (1986) reported a change in management in 2.2 percent (4 of 180) of patients, based on findings obtained on IVU in a population preselected by excluding men with hematuria, infections, and a history of bladder tumors. Pinck, Corrigan, and Jasper (1980) deferred TURP in favor of a more urgent intervention in 2.5 percent (14 of 557). These data indicate that a change in management would result in about 10 percent of the 25 percent of patients in whom the imaging study is "abnormal."

The presence or history of hematuria, renal insufficiency, urinary tract infection, and/or history of stones or prior urinary tract surgery increases the likelihood that IVU or ultrasonography will demonstrate clinically significant findings (Juul, Torp-Pedersen, and Nielsen, 1989 ; Kreel, Elton, Habershon, et al., 1974 ; Andersen, Jacobsen, and Strandgaard, 1977 ; Christofferson, and Moller, 1981 ; Wasserman, Lapointe, Eckmann, et al., 1987 ; Wilcox, and Mitchell, 1977 ; Butler, Donnelly, and Komaranchat, 1978 ; Morrison, 1980 ; Bauer, Garrison, and McRoberts, 1980).

Donker and Kakiailatu (1978) reported that by screening those men with urinary tract infections, gross hematuria, and renal insufficiency, they would have diagnosed almost all of the abnormal findings in their population of 307 men with BPH.

Although there are no conclusive data on the combined incidence of the important clinical predictors listed above, the panel estimates that approximately one-third of all men with BPH have one or another indication for urinary tract imaging.

Assuming that an indication for renal imaging exists, a number of investigators strongly recommend, instead of IVU, ultrasonography combined with a KUB and a determination of the renal function by measurement of the serum creatinine (Matthews, Quayle, Joseph, et al., 1982 ; Lilienfeld, Berman, Khedkar, et al., 1985 ; Cascione, Bartone, and Hussain, 1987 ; Fidas, Mackinlay, Wild, et al., 1987 ; Hendrikx, Doesburg, Reintjes, et al., 1988 ; Solomon, and Van Niekerk, 1988 ; Stavropoulos, Christodoulou, Chamilos, et al., 1988).

This policy is sound if the level of renal insufficiency prohibits the performance of an IVU (which is rarely the case). Ultrasonography is more specific in determining the nature of a renal mass lesion, thus not requiring as many confirmatory studies as IVU. In a significant percentage of patients, however, the imaging will be inadequate (7.5 percent). For the evaluation of hematuria, IVU has been found to be the more sensitive study.