# Optional Diagnostic Tests

Patients with a normal initial evaluation, and only mild symptomatology on the AUA Symptom Index (scores of 0 to 7), do not need additional diagnostic evaluation. These patients should be placed in a watchful waiting program and followed. Urinary flowrate, postvoid residual urine, and pressure-flow urodynamic studies are optional in the evaluation+/- 8). Urethrocystoscopy is optional during later evaluation if invasive treatment is being strongly considered.

The urinary symptoms commonly seen in men with BPH are not specific. Urinary tract infection, urethral stricture disease, bladder cancer, and primary bladder disease may mimic the symptoms of BPH. In most cases, the differential diagnoses can be ruled out by the medical history or the basic evaluation. In some cases, further diagnostic evaluation is warranted.

After reviewing the available diagnostic tests, including urethrocystoscopy, urinary flowrate, and pressure-flow studies, the panel concluded that evidence was insufficient to mandate use of any of these tests in patients with moderate-to-severe symptoms prior to offering treatment alternatives. The decision to perform additional diagnostic testing should be left to clinical judgment. It is very unlikely, however, that a patient will require more than one or two optional diagnostic tests.

It is appropriate for the physician to offer treatment alternatives to the patient without performing any further diagnostic tests. Especially if the patient chooses watchful waiting or noninvasive therapy, invasive diagnostic tests may not be necessary. Conversely, even if optional diagnostic tests were not performed initially and if the patient elects an invasive treatment option, it may be appropriate for the physician to consider further evaluation.

## Optional Tests in Men with a Guideline for BPH Surgery

There is a treatment-policy guideline for surgery (Decision Diagram, Attachment A) if the patient has refractory urinary retention (failing at least one attempt of catheter removal) or any of the following conditions, clearly secondary to BPH: recurrent urinary tract infection, recurrent gross hematuria, bladder stones, or renal insufficiency (see chapter 7).

In this situation, the performance of optional diagnostic tests is not necessary unless there is reason to suspect that the patient's retention may be due to primary bladder disease. In that case, urodynamic studies (for example, filling cystometry) may be helpful. Pressure-flow urodynamic studies are not possible if the patient cannot urinate. Urethrocystoscopy is optional prior to the operative procedure to help plan the most prudent approach.

The presence of infection and hematuria in patients should prompt appropriate evaluations for these conditions prior to treatment of the BPH.

## Uroflowmetry

Urinary flowrate recording (uroflowmetry) is an optional test in the evaluation of men with prostatism.

Uroflowmetry is the electronic recording of the urinary flowrate throughout the course of micturition. It is a common, noninvasive urodynamic test used in the diagnostic evaluation of patients presenting with symptoms of bladder outlet obstruction. The results of uroflowmetry are nonspecific for causes of the symptoms. For example, an abnormally low flowrate may be caused by an obstruction (hyperplastic prostate, urethral stricture, meatal stenosis, or other obstruction) or by weakness of the detrusor (bladder) muscle. The following statements can be made regarding uroflowmetry:

- Flowrate recording is the single best noninvasive urodynamic test to detect lower urinary tract obstruction. Current evidence, however, is insufficient to recommend a given "cutoff" value to document the appropriateness of therapy.
- The peak flowrate (Q[max]) more specifically identifies patients with BPH than does the average flowrate (Q[ave]).
- Although Qmax decreases with advancing age and decreasing voided volume, no age or volume correction is currently recommended for clinical practice.
- Although considerable uncertainty exists, patients with a Q[max] greater than 15 mL/sec appear to have somewhat poorer treatment outcomes after prostatectomy than patients with a Q[max] of less than 15 mL/sec.
- A Q[max] of less than 15 mL/sec does not differentiate between obstruction and bladder decompensation.

### Procedure

The procedure for uroflowmetry has been standardized. The patient should be instructed prior to the test, but not distracted by verbal comments or observation during the actual flowrate recording. Flowrate should be measured with the patient in his normal voiding position (supine, sitting, or standing), in private, and when he feels the urge to void. Although bladder filling is needed, the patient should not be encouraged to wait until he cannot hold his urine any longer or until the bladder is severely distended. It is helpful to inquire whether the patient judged the voiding act normal according to his own habits. If doubts exist whether the voiding was representative of the patient's normal voiding, the test should be repeated and the first measurement disregarded.

### Measured Variables

According to the International Continence Society (ICS) Committee on Standardization of Terminology (Abrams, Blaivas, Stanton, et al., 1988), urinary flow may be described in terms of rate and continuous or intermittent pattern. Flowrate is defined as the volume of fluid expelled via the urethra per time unit and is expressed in milliliters per second (mL/sec). Voided volume, environment, patient position, the mode of filling (diuresis or catheter), and the type of fluid used should be specified.

Voided volume is defined as the total volume expelled via the urethra. Maximum or peak flowrate (Q[max]) is the maximum measured flowrate. Average flowrate (Q[ave]) is the voided volume divided by flowtime (meaningful only if flow is continuous), and flowtime is the time during which measurable flow occurs. In the case of intermittent flow, the intervals between flow episodes are disregarded. The parameter of voiding time (total duration of micturition) is reported.

One aspect of interpreting flowrate recordings involves discrepancies between manual and automatic (by the machine) readings. Grino, Bruskewitz, Blaivas, et al. (1992) analyzed a data base of 1,645 patients who voided a total of 23,857 times. The manually read Q[max] values were on average 1.5 mL/sec lower than the automatic machine-read values. Artifacts of >2 mL/sec were found in 20 percent of tracings, and artifacts of >3 mL/sec were found in 9 percent of tracings. The manually read peak flowrate resulted in CIs 15 to 25 percent smaller than for the machine-read values, thus improving the statistical power of peak flowrate recordings when treatment groups are compared.

### Correlation Between Flowrate and Voided Volume

An important issue is whether a flowrate measurement can be interpreted without considering the voided volume. Many investigators have studied the dependence of Q[max] on voided volume and have developed nomograms reflecting this relationship (von Garrelts, 1956, 1957, 1958 ; Scott, and McIlhaney, 1961 ; Beck, and Gaudin, 1969 ; Susset, Picker, Kretz, et al., 1973 ; Drach, Layton, and Binard, 1979 ; Drach, and Steinbronn, 1986 ; Siroky, Olsson, and Krane, 1979, 1980 ; Layton, and Drach, 1981 ; Ryall, and Marshall, 1982 ; Balslev-Jorgensen, Jensen, Bille-Brahe, et al., 1986 ; Haylen, Ashby, Sutherst, et al., 1989). There is no universally accepted nomogram for flowrate correction.

To describe the relationship between Q[max] and voided volume, the panel combined the results of 12 studies involving 817 asymptomatic men from 25 to more than 60 years of age who voided a total of 1,900 times. The mean Q[max] and the plus-or-minus standard deviations for the reported Q[max] values were calculated from these pooled data sets for volumes from 100 to 500 mL and plotted in Figure 2. The reported minimum and maximum Q[max] values for each volume category were also plotted.

Figure 2. Relationship between Q[max] and voided volume

In addition, the panel reviewed data submitted to the FDA from the phase III finasteride trials (Merck, Sharp & Dohme Research Laboratories, 1992). The data demonstrate minimal Q[max] volume dependence in men with BPH if the voided volume is >125 mL.

Although Q[max] partially depends on the voided volume and age, the range of volumes for which this correlation can be expressed as a simple mathematical formula or a nomogram is uncertain. The nomograms themselves vary considerably. Furthermore, Q[max] may not be as volume dependent in men with BPH as it is in normal men. Therefore, no recommendation can be made for a single volume correction technique. If volume correction is not utilized, the inaccuracy of flowrates with voided volumes of <125 to 150 mL should be recognized.

### Sensitivity and Specificity

The crucial issues for flowrate recording in regard to patients with symptoms of prostatism are: (1) the test's sensitivity in detecting patients with BPH, (2) the test's specificity in excluding those with symptoms due to some other cause than BPH, and (3) the test's ability to identify those patients most likely to have a positive outcome following treatment and those patients who most likely will not have a positive outcome.

#### Test Sensitivity.

Despite its limitations, flowrate recording has demonstrated some sensitivity in diagnosing BPH (Scott, Cardus, Quesada, et al., 1967). Shoukry, Susset, Elhilali, et al. (1975) found that Q[max] correlated better than symptoms with the presence or absence of obstruction as determined by pressure-flow studies. Siroky, Olsson, and Krane (1979, 1980) concluded that uroflowmetry was able to separate physiologically unobstructed and obstructed patients. Gleason, Bottaccini, Drach, et al. (1982) found that Q[max] distinguished between normal men and patients with BPH, urethral stricture, or prostatitis. However, they also noted that a subgroup of patients with a decompensated detrusor muscle could not be separated from the obstructed men on the basis of Q[max] alone. In a similar study, significant differences were noted in both Q[max] and Q[ave] between normal volunteers and 16 patients with BPH who were to undergo prostatectomy (Groshar, Embon, Koritny, et al., 1991). After prostatectomy, both parameters improved significantly in the 16 patients, and the postoperative values approximated those of the normal population.

#### Test Specificity.

Chancellor, Blaivas, Kaplan, et al. (1991) found that flowrate recording cannot distinguish between bladder outlet obstruction and impaired detrusor contractility as the cause for a low Q[max]. None of 8 measured, noninvasive urodynamic parameters was significantly different for 31 patients with outlet obstruction than for 14 patients with impaired detrusor contractility (Table 6).

Table 6. Inability of eight urodynamic parameters to separate obstruction from detrusor decompensation

Parameters | Obstruction (n = 31) | Detrusor failure (n = 14)
Time to Qmax (sec) | 7.6 ± 4.3 | 11 ± 8.9
Voiding time (sec) | 41 ± 20 | 65 ± 62
Qmax (mL/sec) | 8.5 ± 2.1 | 8.8 ± 2.7
Qave (mL/sec) | 4.4 ± 1.4 | 4.3 ± 1.7
Qmax/time to Qmax | 1.3 ± 0.75 | 0.89 ± 0.64
Time from Qmax to 95% of volume voided/time to void initial 95% of volume | 0.76 ± 0.13 | 0.66 ± 0.21
Time to Qmax/total voiding time | 0.2 ± 0.11 | 0.28 ± 0.18
Qmax/Qave | 2.0 ± 0.62 | 2.1 ± 0.5

Note: Qmax = peak flow rate. Qave = average flow rate.

Source: Chancellor, Blaivas, Kaplan, et al., 1991.

### Predictive Value of Uroflow

Abrams (1977) and Abrams, Farrar, Turner-Warwick, et al. (1979) studied the value of uroflowmetry prior to prostatectomy. Failure rates for surgery were found to decrease with the addition of flowrate measurement to symptom assessment in preoperative evaluation.

Q[max] appears to predict surgical outcome in some studies. In one study (Jensen, Bruskewitz, Iversen, et al., 1984), 53 patients underwent prostatectomy based on clinical indication alone. The study population was divided according to Q[max] into three groups: Q[max] less than 10 mL/sec, between 10 and 15 mL/sec, and greater than 15 mL/sec. All three groups experienced improvements in their symptom score after surgery, but the group with a Q[max] less than 10 mL/sec before treatment had a better overall subjective outcome as assessed by global subjective judgment.

In a report that included men studied before and 6 months after prostatectomy (Jensen, Jorgensen, and Mogensen, 1988a), patients were divided into three groups: Q[max] greater than 15 mL/sec; Q[max] between 10 and 15 mL/sec; Q[max] less than 10 mL/sec. Subjective evaluation revealed an overall symptomatic improvement rate of 89 percent after surgery. The difference in success rates for men falling above or below the cutoff value of Q[max] = 10 mL/sec was not significant (p <0.2). When a Q[max] cutoff of 15 mL/sec was used, success rates for men above or below the cutoff value differed significantly (p <0.02) as shown in Table 7.

Table 7. Symptomatic improvement based on pretreatment Qmax; statistically significant difference in probability for treatment success below or above Qmax cutoff value of 15 mL/sec

Symptomatic Improvement | Qmax > 15 mL/sec | Qmax > 10 and < 15 mL/sec | Qmax < 10 mL/sec
Much better | 12 patients | 31 patients | 76 patients
No change | 5 patients | 3 patients | 7 patients
Success rate | 71% | 91% | 92%
Success rate if Qmax > 10 as cutoff = 84%
Success rate if Qmax < 15 as cutoff = 92%

Note: Qmax = peak flowrate.

Source: Jensen, Jorgensen, and Mogensen, 1988a.

Sensitivity and specificity analysis from the same study, using the Q[max] cutoff as the discriminator, revealed the results shown in Table 8.

Table 8. Diagnostic specificity and sensitivity of flowrate recording using different Qmax cutoff values

Qmax cutoff value | Specificity = p(S\|Q)[1] | Sensitivity = p(!S\|Q)[2]
10 | 92% | 16%
15 | 91% | 29%

1. p(S|Q) = probability for successful outcome (S) if Qmax ≥ indicated value.

2. p(!S|Q) = probability for unsuccessful outcome (!S) if Qmax ≥ indicated value.

Note: Qmax = peak flowrate.

Source: Jensen, Jorgensen, and Mogensen, 1988a.

Unfortunately, not all investigators have utilized 15 mL/sec as the cutoff. McLoughlin, Gill, Abel, et al. (1990), using urodynamic testing and a cutoff of 12 mL/sec, evaluated 108 men with prostatism before and 1 year after surgery and derived the following conclusions:

1. A Q[max] less than 12 mL/sec as indicator for obstruction would subject only 3 percent of patients unnecessarily to TURP.
2. Routine pressure-flow studies or cystometrograms are not indicated, but the screening of flowrates followed by further urodynamic testing in patients with a Q[max] of greater than 12 mL/sec is recommended. Studies to rule out uninhibited detrusor contractions are also indicated if symptoms persist after treatment.
3. The data confirm the independent predictive value of symptoms and flowrate.

Very low flowrates do not appear to portend poor treatment outcome. In one study (Dorflinger, Bruskewitz, Jensen, et al., 1986) of 84 patients undergoing surgery for symptomatic BPH, patients with a low preoperative Q[max] (less than 7 mL/sec) improved symptomatically as much as patients with a Q[max] greater than 7 mL/sec.

### Conclusions

Neither subjectively assessed symptoms nor quantified symptom-score analysis correlate strongly with uroflowmetry measurements. Both are independent assessment tools. Patients with a peak flowrate (Q[max]) greater than 15 mL/sec have somewhat poorer outcomes than those with a Q[max] less than 15 mL/sec (although the majority of patients still improve). Other investigators report similar findings for different Q[max] cutoff values (for example, 12 mL/sec). Patients with very bothersome symptoms suggestive of prostatism, but having a Q[max] greater than 15 mL/sec, may benefit from further urodynamic testing (that is, pressure-flow studies) to reduce the number of surgical treatment failures. A Q[max] less than 15 mL/sec does not differentiate between outflow obstruction and detrusor impairment. Apparently, no minimal threshold of Q[max] reliably diagnoses detrusor failure or predicts a poor surgical outcome. The wide range of Q[max] "cutoffs" used by State PROs is not surprising. Every flowrate threshold used can be supported by at least one small study.

Until long-term outcome studies clearly establish the role of flowrate measurements, their use should be optional.

## Postvoid Residual Urine

Measurement of postvoid residual urine (PVR) is an optional test in the evaluation of men with prostatism. The panel believes that present PRO requirements, for certain amounts of residual urine before a prostatectomy is considered appropriate, cannot be justified on the basis of current data. A high PVR may suggest a slightly higher likelihood of failing watchful waiting.

Postvoid residual urine is the volume of fluid remaining in the bladder immediately following the completion of micturition. Studies indicate that residual urine normally ranges from 0.09 to 2.24 mL, with the mean 0.53 mL (Hinman, and Cox, 1967). Seventy-eight percent of normal men have residual urine volumes of less than 5 mL, and 100 percent have volumes of less than 12 mL (Di Mare, Fish, Harper, et al., 1963). The following points can be made regarding PVR:

- Residual urine volume measurement has significant intraindividual variability that limits its clinical usefulness.
- Residual urine volume does not correlate well with other signs or symptoms of prostatism.
- Large residual urine volumes may predict a slightly higher failure rate with a strategy of watchful waiting. However, the threshold volume defining a poorer outcome is uncertain.
- It is uncertain whether residual urine volume predicts the outcome of surgical treatment.
- It is uncertain whether residual urine volume indicates impending bladder or renal damage.
- Residual urine volume can be measured with sufficient accuracy noninvasively by transabdominal ultrasonography. The measurement variation due to the method is less than the biologic range of patient PVR variation.

### Methods of Measurement

PVR measurement can be performed by noninvasive (ultrasound) and by invasive (catheterization) methods. The most common method is urethral in-and-out catheterization. Invasive techniques are accurate if performed correctly, but carry a small risk of discomfort, urethral injury, urinary tract infection, and transient bacteremia (which has not been quantified in the literature).

Although in-and-out catheterization is accepted as the "gold standard" for measuring PVR, two studies note technical problems with this technique. Stoller and Millard (1989) assessed the accuracy of PVR measurement with in-and-out catheterization done by urological nurses in 515 patients. In 26 percent of patients, the bladder was not empty after catheterization. In an initial group of 116 male patients, 30 percent had an inaccurate assessment. The mean difference in this group between the initial and the actual residual volume was 76 mL. In another group of 106 male patients, only 14 percent (n = 15) had inaccurate initial measurements with a mean difference of 85 mL. This second group was investigated after the nurses were educated regarding techniques to improve complete draining of the bladder.

Purkiss (1990) evaluated 15 men using a similar method. Ten men in acute urinary retention were catheterized and their bladders drained. A known amount of normal saline was then injected and a 10-mL sample obtained from the bladder. The same experiment was conducted in five men using chronic indwelling catheters. A PVR of 98 mL (range 40 to 385 mL) was noted in the 10 men catheterized for acute retention, and a PVR of 15 mL (range 4 to 37 mL) in the 5 men with indwelling catheters.

Based on these findings, it appears that the "gold standard" for measuring PVR, catheterization, is often inaccurate if the person performing the catheterization does not practice techniques to ensure complete emptying. Even then, urine can remain in bladder diverticula and saccules or reflux into the upper tract, causing inaccurate measurements.

Transabdominal ultrasonography, using either a regular B-mode, real-time device or a dedicated unit, is the least invasive method for determining residual urine in men with prostatism. A large number of studies report the accuracy of real-time transabdominal ultrasonography in estimating PVR. All techniques and formulas described in the literature are based on imaging the bladder transabdominally in a transverse and longitudinal orientation, and using either three diameters (length, height, width) or the surface area in the transverse image and the length obtained from the longitudinal image. Bladder volume is estimated by means of the volume formula for a spherical or ellipsoid body.

Although ultrasound is sufficiently accurate for most clinical applications, its cost is a factor. Catheterization is still an appropriate option given the cost and limited office availability of ultrasound units.

However, in addition to standard diagnostic ultrasound instruments for abdominal scanning, there is a much smaller, portable, and less expensive device to measure PVR (BladderScan; Diagnostic Ultrasound). Its reported accuracy is comparable to more expensive ultrasound units and catheterization. With this device, the mean difference between estimated PVR and "true" PVR (that is, by catheterization) was 6.9 mL in 39 measurements taken in 20 children with neurogenic bladders (Massagli, Jaffe, and Cardenas, 1990). In 164 measurements in adult patients, the correlation coefficient was r = 0.79 (Ireton, Krieger, Cardenas, et al., 1990).

### Reproducibility

Birch, Hurst, and Doyle (1988) reported that of 30 men with BPH, 66 percent had wide variations in PVR when three measurements were done on the same day using five different formulas to calculate the volume. In 34 percent of patients, there was no difference among the three measurements. In 58 percent, at least two volumes were significantly different. In 8 percent of patients, all three were different. In most patients, two measurements were statistically similar while the third one yielded quite different results. This study proves that the intraindividual variation of the amount of residual urine is greater than the differences between the various formulas utilized.

Bruskewitz, Iversen, and Madsen (1982) found similarly wide variations of the measured amount when they performed repetitive measurements of PVR (repeated 2-5 times) by in-and-out catheterization on 47 men prior to prostatectomy. They also found no correlation between the amount of residual urine and any urethrocystoscopic or urodynamic findings, symptoms, or the presence or absence of a history of urinary tract infections.

The intraindividual variation in PVR measurement is significant, regardless of the techniques used. Although repeated measurements may minimize the error, this is either costly (noninvasive techniques) or uncomfortable (invasive techniques) for the patient.

### PVR in the Evaluation of Patients with BPH

Shoukry, Susset, Elhilali, et al. (1975) found that 22 percent of 44 men with significant levels of residual urine on intravenous urography (IVU) films had a "normal" Q[max] (peak flowrate). These data indicate a poor correlation between the volume of residual urine and other urodynamic assessments of obstruction severity.

Griffiths and Castro (1970) measured PVR by radiographic methods in 45 men with prostatism and found a reasonable correlation with the amount determined by catheterization, but no correlation with other clinical data such as prostatic size, Q[max], maximal bladder pressure, urethral resistance, and symptom scores. Most investigators believe that large amounts of PVR urine indicate severe obstruction. Yet, Griffiths and Castro (1970) found that 24 percent of the patients with severe obstruction had less than 50 mL of PVR urine.

PVR was found to be of little help in assessing 117 patients with BPH in a study by Abrams and Griffiths (1979), who considered PVR urine an indication of abnormal bladder function or detrusor decompensation rather than evidence for urethral obstruction.

Neal, Styles, Powell, et al. (1987) found a significant association in 253 men between PVR, age, "below normal" (undefined) Q[max], and high urethral resistance. Weak voiding pressure, however, did not correlate well with PVR. The authors concluded that outflow obstruction is related to the development of increasing amounts of PVR urine.

### Predictive Value of PVR

Traditionally, urologists have assumed that increasing amounts of PVR denote BPH progression and are thus an "indication" for surgery. This concept underlies the common inclusion of PVR values in individual State PRO criteria. Unfortunately, data are lacking to support the predictive value of PVR.

Andersen (1982) studied 104 men with BPH and reported two patterns of BPH progression. The slow course was characterized by the development of high levels of PVR that resulted in decompensation of the detrusor muscle and eventually led to urinary retention. The fast course was associated with uninhibited detrusor contractions (UDCs). The amount of PVR, the presence of UDCs, and symptoms correlated poorly in the study. Nevertheless, Andersen recommended PVR as a safety parameter, when measured longitudinally throughout the clinical course of a patient with prostatism.

Jensen, Jorgensen, and Mogensen (1988c) examined the prognostic value of PVR and 14 other clinical and urodynamic variables in relation to outcome of surgery in 120 men with prostatism. They found PVR the second best predictor of outcome, after pressure-flow studies. However, the combination of these two predictors did not allow the authors to predict correctly the outcome in any of 14 patients who failed treatment. The authors did correctly predict all successfully treated patients.

The panel reviewed unpublished data from a randomized trial comparing TURP with watchful waiting (Veterans Affairs Cooperative Study Group). These data demonstrate that PVR does not predict the outcome of surgery, and there appears to be little evidence to support criteria that require a certain amount of PVR before surgery is justified (Wasson, Reda, Bruskewitz, et al., forthcoming ). High PVR did predict, in this trial, a slightly higher failure rate for watchful waiting. However, the majority of men with large residual urine volume did not require surgery during the 3-year duration of the trial.

### Conclusions

The volume of PVR correlates poorly with other signs and symptoms of prostatism. The common assumption, that the amount of residual urine predicts which men will or will not improve after surgery for prostatism, is not adequately supported by enough evidence to mandate use of the test. The test is, therefore, optional in the evaluation of men presenting with prostatism.

The panel believes that present review criteria requirements, for certain amounts of residual urine before a prostatectomy is considered appropriate, cannot be justified on the basis of current data. Requiring the presence of residual urine before offering treatment implies that at least partial bladder decompensation must occur before intervention is appropriate.

Nevertheless, although poorly studied in the literature, monitoring of PVR is a reasonable option for men being followed with BPH or for those selecting nonsurgical therapies. It is likely that high residual urines may lead to a slightly higher failure rate for watchful waiting, but repeat measurements should be considered before making treatment decisions based on PVR values.

Prospective evaluation of the predictive value of PVR is needed. Specifically, the risks associated with given volumes must be determined in order to ascertain what PVR values are associated with a risk for urinary retention, infection, or poor treatment outcome.

## Pressure-Flow Studies

Pressure-flow studies are optional in the evaluation of men with prostatism.

Pressure-flow studies differentiate between patients with a low Q[max] secondary to obstruction and those whose low Q[max] is caused by a decompensated or neurogenic bladder. Pressure-flow studies may also identify high-pressure obstruction in symptomatic men with normal flowrates.

Evidence for the usefulness of pressure-flow studies to predict surgical failure is equivocal. Some investigations have reported reduced failure rates, while others have reported that pressure-flow studies performed no better than Q[max] measurements in this regard. Some patients who are excluded from surgery based on the pressure-flow test may still benefit from surgery.

Pressure-flow studies are most useful for distinguishing between urethral obstruction and impaired detrusor contractility. They should be performed when the distinction between the two will affect therapeutic decisions. Patients with a history of neurologic diseases known to affect bladder or sphincteric function, as well as patients with normal flowrates (Q[max] > 15 mL/sec) but bothersome symptoms, may also benefit from urodynamic evaluation and especially if surgical therapy is contemplated.

Pressure-flow studies have been developed to fill a diagnostic gap. Flowrate measurements, although useful to document the presence or absence of an impairment of the urinary stream, cannot differentiate between obstruction and decreased bladder contractility. Neither can they differentiate between types of obstruction (for example, between BPH and urethral stricture). Urodynamic experts have, therefore, developed tests that differentiate between patients who have a low Q[max] secondary to obstruction and those who have an impaired Q[max] secondary to detrusor failure or other causes.

### Methods of Measurement

Pressure-flow tests measure pressure in the bladder during voiding. To monitor intravesical pressure (P[ves]), it is necessary to introduce a recording device into the bladder either transurethrally or suprapubically. A rectal recording device is often used to subtract the intrarectal (that is, intra-abdominal) pressure from the intravesical pressure. The difference between the intravesical and the intrarectal pressure is the detrusor pressure (P[det]), reflecting the pressure generated by the bladder muscle alone.

A detrusor pressure of greater than 100 cm H[sub2]0 at the time of the peak flowrate would indicate obstruction according to Smith (1968). Lower "obstructive" pressures have been recommended by other investigators. Flowrate (Q[max]) and voiding pressure have also been related in the form of a urethral resistance factor, according to a concept derived from rigid-tube hydrodynamics theory (Griffiths, 1975). The urethral resistance factor is calculated as the ratio between the intravesical pressure at Q[max] over Q[max]^2 (R = P/Q^2 or P[det]Q[max]/Q[max]^2). A urethral resistance greater than 0.6 is believed to indicate obstruction.

However, the urethra behaves like an elastic, not a rigid, tube. This limits the value of resistance measurements calculated in the usual fashion (Spangberg, Terio, Ask, et al., 1991). Rather than combining the data in a single factor, the International Continence Society recommends plotting them in the form of a pressure-flow diagram (Abrams, Blaivas, Stanton, et al., 1988). A subgroup of patients with equivocal results may or may not have obstruction, and their poor flow may be due to a nonrepresentative micturition or a weak detrusor. The presence of this equivocal group demonstrates that a single "urethral resistance factor" cannot capture the complex relationship between intravesical pressure and flow.

The value of pressure-flow plots is accepted by many urodynamic experts. Yet there is little standardization in interpretation of these plots and few clear "cutoff" values for defining obstruction as opposed to nonobstruction. Investigators have proposed various ways to present the same sets of data and claim superior differentiation between patient groups (Abrams, Farrar, Turner-Warwick, et al., 1979 ; Jensen, Jorgensen, and Mogensen, 1988b, 1988d ; Schafer, Noppeney, Rubben, et al., 1988 ; Schafer, Rubben, Noppeney, et al., 1989 ; Spangberg, Terio, Ask, et al., 1991). This variability in data presentation and definition has made it difficult to analyze the evidence that supports the use of such pressure-flow plots.

### Predictive Value of Pressure-Flow Studies

The most important issue to address is predictive value. To what extent can invasive pressure-flow studies identify patients who will not improve after surgical treatment of their urinary symptoms? To what extent does the addition of pressure-flow studies enable the clinician to separate the truly obstructed from the unobstructed patients? To what extent does this distinction predict the outcome of BPH therapy? Unfortunately, only a limited number of reports present outcome data addressing the value of pressure-flow studies in reducing the symptomatic failure rate of surgery.

Bruskewitz, Jensen, Iversen, et al. (1983) studied prospectively the outcome in 46 patients with prostatism. Patients were divided into two groups with urethral resistance either less than or greater than 0.6. The urethral resistance was correlated with symptom scores and with Q[max], but not with the size or resected weight of the prostate. Eighty-nine percent of the patients with a resistance factor less than 0.6 reported global subjective improvement, compared with 92 percent of patients with a resistance factor greater than 0.6 (not significant). The authors concluded that in patients with moderate prostatism, a cutoff value of R = 0.6 does not predict either indirect health outcomes (Q[max] , detrusor pressure, resistance) or direct health outcomes (symptom score assessment, global subjective symptom assessment) after surgery.

Abrams, Farrar, Turner-Warwick, et al. (1979) examined 190 men (age 47-85) who underwent prostatectomy. Followup data after surgery were available for 152 patients. The decision to perform surgery was based on urodynamic testing, but the report did not clarify which criteria were applied to the decision to operate and whether the surgeons were blinded concerning the preoperative urodynamic evaluation. The patients were considered improved after surgery if their Q[max] was greater than 15 mL/sec at a pressure less than 100 cm H[sub2]0. Subjectively, 88 percent of the patients improved, 12 percent showed no change, and none worsened postoperatively. Objective assessment revealed the following outcomes:

- Improved symptoms, relief of obstruction: 76.0 percent.
- Improved symptoms, partial relief of obstruction: 10.0 percent.
- Improved symptoms, no relief of obstruction: 2.5 percent.
- Symptoms not improved, relief of obstruction: 7.5 percent.
- Symptoms not improved, no relief of obstruction: 4.0 percent.

Objectively assessed, 86 percent of patients improved as compared with the 88 percent who improved subjectively. Q[max] increased from 6.9 [pm]4.1 mL/sec to 20+/-7.1 mL/sec. In an earlier study (Abrams, 1977), the inclusion of urodynamic data in the preoperative evaluation and indication for surgery reduced the subjective failure rate to 12 percent, down from 28 percent when patients were certified as candidates for surgery without the urodynamic data. However, a 28-percent failure rate is significantly higher than that reported in other TURP series.

Another study (Abrams, and Griffiths, 1979) used pressure-flow plots in addition to flowrate measurement. The study found that in about half the cases the patients with prostatism could be correctly classified as obstructed or nonobstructed by Q[max] alone, but that the addition of the detrusor pressure at Q[max] allowed correct classification in two-thirds of patients. Combining the two parameters into a single urethral resistance factor did not help in the two-thirds group. The remaining one-third of the patients were assessed by pressure-flow plot. In many of these patients, both pressure and Q[max] were low, indicating a decompensating detrusor muscle as the source for the low Q[max].

Jensen and Andersen (1990) recommended invasive urodynamic testing for patients with a Q[max] >15 mL/sec. For the population in their study, this results in an additional 9 percent of patients excluded from surgery and a decrease in failure rate to 8.3 percent. The support for this recommendation has to be questioned, however, in light of an earlier study by Jensen, Jorgensen, and Mogensen (1988d) that found most unsatisfied patients are incorrectly classified preoperatively even with urodynamic testing (Table 9).

Table 9. Urodynamic variables used to predict outcome after surgery

Variables | Overall percent correctly classified | Percent unsuccessful patients correctly classified | Percent successful patients correctly classified
Pressure-flow plot (P/Q) and residual urine (PVR) | 88.3% (106/120) | 0% (0/14) | 100% (106/106)
P/Q, PVR, Qmax, detrusor pressure, irritative symptom score | 88.3% (106/120) | 0% (0/14) | 100% (106/106)

Note: Qmax = peak flowrate.

Source: Jensen, Jorgensen, and Mogensen, 1988d.

In a study by Kuo and Tsai (1988), 50 patients (age 51-84, mean age 65) were evaluated urodynamically and by symptom analysis before and after prostatectomy. Symptom analysis was assessed subjectively without a scoring system and postoperative results were reported as "good," "fair," or "worse." The results of the urodynamic tests were not made known to the surgeon.

Preoperatively, 23 of the 50 patients had a Q[max] less than 10 mL/sec; 17 patients had a Q[max] between 10 and 15 mL/sec; and 10 patients had a Q[max] of greater than 15 mL/sec. Thirty-three patients had high-pressure obstruction (HPOB). Nine patients had low-pressure obstruction (LPOB). Eight patients had low-pressure and no obstruction (LPNOB), presumably due to detrusor failure. The subjective evaluation of success according to the preoperative classification is shown in Table 10.

Table 10. Correlation between preoperative urodynamic data and outcome following surgery

| Outcomes
Patients | Good | Fair | Worse
HPOB | 31/33 (94%) | 2/33 (6%)
LPOB | 2/9 (22%) | 6/9 (67%) | 1/9 (11%)
LPNOB | 1/8 (12.5%) | 2/8 (25%) | 5/8 (62.5%)
Qmax < 10 mL/sec | 18/23 (78%) | 4/23 (17%) | 1/23 (5%)
Qmax 10-15 mL/sec | 14/17 (82%) | 1/17 (6%) | 2/17 (12%)
Qmax > 15 mL/sec | 2/10 (20%) | 5/10 (50%) | 3/10 (30%)
Overall outcome results | 68% | 20% | 12%

Note: HPOB = high-pressure obstructed bladder, LPOB = low-pressure obstructed bladder, LPNOB = low-pressure nonobstructed bladder, Qmax = peak flowrate.

Source: Kuo and Tsai, 1988.

The success rate in patients with HPOB was better (p <0.005) than in patients with LPOB and LPNOB. However, the success rate was also better (p <0.005) in patients with a Q[max] less than 15 mL/sec as compared with a Q[max] greater than 15 mL/sec. The difference in success rate between a Q[max] less than 10 mL/sec and a Q[max] between 10 and 15 mL/sec was not significant: 78 percent and 82 percent, respectively. Based on these findings, Kuo and Tsai (1988) suggested prostatectomy for patients with a Q[max] less than 15 mL/sec or patients with a higher Q[max]who have high-pressure obstruction proven by pressure-flow studies. It is difficult to explain how, in the low-pressure, nonobstructed group, 62.5 percent of patients actually worsened (Table 10). This failure rate is higher than any reported in the literature.

Schafer, Noppeney, Rubben, et al. (1988) and Schafer, Rubben, Noppeney, et al. (1989) used sophisticated, computerized analysis of pressure-flow data to define passive and dynamic urethral resistance measures. They documented that approximately 25 percent of patients undergoing TURP are not obstructed, based on the investigators' criteria, although these patients may have a low Q[max]. The improvement rate based on objective measures (Q[max] and PVR) was 100 percent in patients categorized as severely obstructed, but was lower in the mildly obstructed and nonobstructed patients. Direct health outcome data were not reported by these investigators.

The Schafer model has been used and expanded by other investigators (Spangberg, Terio, Ask, et al., 1991), but correlation of the objective results with direct health outcomes (subjective results) is again lacking. Others have employed computer programs to analyze pressure-flow plots, but also do not report outcome data (Rollema, van Mastrigt, and Janknegt, 1991 ; Rollema, and van Mastrigt, 1991). The details of the analysis and the computer program are not discussed in an outcomes context. These computer-assisted urodynamic assessments need further evaluation before they can be recommended routinely.

### Conclusions

Pressure-flow studies provide much more specific insight into detrusor function and the etiology of voiding dysfunction than do flowrate measurements. However, the limited number of outcome-based investigations performed demonstrate a modest additional value of pressure-flow studies over symptom and flowrate evaluation. The benefit of pressure-flow studies is clearest in those patients who have a Q[max] >15 mL/sec or in whom the initial evaluation suggests bladder dysfunction rather than BPH as the cause of patient symptoms. Moreover, intraindividual and interobserver variability have not been adequately defined for these studies. Although pressure-flow plots are generally recognized to be more informative than measurement of urethral resistance, interpretation of such plots has not been standardized.

Given the uncertainties that exist concerning the pressure-flow study, its use should not be mandated in routine cases at the present time. It is, however, an appropriate optional test in patients for whom the distinction between urethral obstruction and impaired detrusor would affect therapeutic decisions. In addition, pressure-flow studies are appropriate in patients with underlying neurologic disease that may affect detrusor or sphincteric function.

Prospective trials to demonstrate the predictive value of pressure-flow studies are needed before further recommendations can be made.