# Future Research Needs

The panel finds an overall lack of high-quality information on the natural history, diagnosis, and treatment of BPH. This lack of high-quality data has two results for the development of diagnostic and treatment guidelines. First is an inability to construct a diagnostic algorithm based on classic decision analysis methodology. Second, and more important, are the wide ranges of uncertainty around many treatment outcomes, which can make truly informed patient decisionmaking difficult. Because of FDA requirements, information on new treatments (especially drug therapies) permits reasonable estimates of treatment outcomes by the time these new treatments reach the marketplace. By contrast, outcomes of watchful waiting, surgery, and some device therapies are less certain.

In many ways, the panel's review of the BPH literature raised more questions than answers. The questions, however, provide the basis for a high-priority BPH research agenda for the next decade. Some of these questions will be addressed by trials currently being planned by the National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK), within the National Institutes of Health, and by the American Urological Association.

## Natural History and Epidemiology

Needed in the area of BPH natural history and epidemiology is research to:

- Define the prevalence of BPH symptoms in the aging male population and investigate possible ethnic and regional differences.
- Define the natural history of untreated BPH (progression) in terms of the probabilities and rates of further prostatic enlargement; changes in symptom severity, uroflow, and measures of urodynamic obstruction; urinary retention; infection; bladder dysfunction; and renal insufficiency.
- Determine whether disease progression (worsening of symptoms or development of complications) can be predicted by baseline assessment of symptoms, prostate size, uroflow, residual urine, or degree of urodynamic obstruction.
- Determine the prevalence of "silent" but clinically significant BPH.

## Diagnosis and Initial Management

Research is needed to:

- Define the sensitivity, specificity, and reliability of symptom score analysis, uroflow, postvoid residual urine, and pressure-flow urodynamic tests for aging men with voiding dysfunction.
- Determine the predictive value of symptom score analysis, uroflow, postvoid residual urine, pressure-flow urodynamics, and urethrocystoscopy in men with BPH treated by watchful waiting and surgery to assess whether these tests can predict a favorable or unfavorable outcome of treatment.
- Determine the relative predictive values of the various pressure-flow analysis techniques (nomograms, plots, computer-assisted analysis).
- Determine whether routine PSA testing in men with prostatism decreases the probability of death or significant morbidity from prostate cancer.

## Treatment

In the treatment area on the BPH research agenda is the need to standardize the collection of treatment outcome data in clinical trials and medical effectiveness studies to include:

- Number of BPH patients whose symptoms improve, stay the same, or worsen.
- Magnitude of symptom change measured by the AUA Symptom Index.
- improvement in Q[max].
- Number of patients who subsequently develop impotence, ejaculatory dysfunction, incontinence, and drug side effects.
- Number of patients who subsequently require surgical intervention for BPH treatment failure.
- Number of patients who require surgical or invasive intervention for surgical complications.
- Number of patients who "cross over" to other BPH treatment options.

In addition, the benefits and harms of existing and emerging BPH therapies need to be defined with enough certainty to permit meaningful comparisons among relative "net benefits" of treatment options.

Patient preferences need to be assessed for all existing and emerging BPH treatment options. The factors that influence patient preference decisions need to be determined.

An ongoing, multicentered technology assessment program needs to be developed to evaluate the effectiveness of new BPH treatment strategies in routine practice compared with standard therapies.

## Quality of Life

Quality-of-life measurement tools that are reliable, valid, and responsive to change need to be developed for BPH patients.

Quality-of-life measurement needs to be incorporated into all clinical trials and long-term BPH treatment effectiveness studies.

## Economics

Methods to collect cost information need to be incorporated into trials that measure the long-term effectiveness of each treatment option. The cost-effectiveness of optional diagnostic tests (PSA, uroflow, PVR, pressure-flow studies, urethrocystoscopy) needs to be determined.