# BPH Diagnosis Summary

The diagnostic recommendations and options summarized here are analyzed and discussed in greater detail in the chapters that follow.

## Guideline Applicability

This Clinical Practice Guideline is intended to apply only to men over the age of 50 with classic symptoms of prostatism, but with no other severe or confounding medical morbidities (for example, diabetes or neurologic disease) or other known causes of voiding dysfunction (for example, urethral stricture or neurogenic bladder). BPH patients to whom the guideline applies would not be at increased risk from surgery or other recognized treatments for BPH. The BPH Guideline Panel estimated that approximately two-thirds of BPH patients who now seek evaluation of their condition would fall within the confines of the diagnostic and treatment recommendations in this Clinical Practice Guideline.

If, however, the results of the initial evaluation of the patient are not consistent with the diagnosis of BPH, or if they reveal additional pathologic findings, then further diagnostic testing is warranted. For example, if microscopic hematuria is identified in the initial evaluation, then the patient is automatically "out of" the diagnostic guideline for BPH, at least until his hematuria has been adequately evaluated. Similarly, the identification of palpable induration or nodularity of the prostate on digital rectal examination places the patient outside of the following diagnostic recommendations because of heightened suspicion of prostate cancer.

## Initial Evaluation

The following steps are recommended in the initial evaluation of all patients presenting with prostatism:

- Detailed medical history to identify other causes of voiding dysfunction and comorbidities that may complicate treatment.
- Physical examination including a digital rectal examination (DRE) and a focused neurologic examination.
- Urinalysis by dipstick testing or microscopic examination of the sediment.
- Measurement of serum creatinine.

Measurement of serum prostate-specific antigen (PSA) is optional.

Because of little evidence documenting the importance of the individual items included in the basic evaluation, an evidence-based review of this area was not possible. The panel nevertheless reached unanimous agreement that these items, except for PSA testing, should be included in the basic evaluation. PSA testing is optional because of the uncertain value of routine PSA testing in men with BPH, especially in men over age 70.

## Symptom Assessment

The American Urological Association (AUA) Symptom Index is recommended as the symptom-scoring instrument to be used in the initial assessment of each patient presenting with symptoms of prostatism. When the AUA system is used, symptoms should be classified as mild (0 to 7), moderate (8 to 19), or severe (20 to 35). This symptom score should be the primary determinant of treatment response or disease progression in the followup period.

The use of the self-administered AUA Symptom Index is recommended. This tool consists of seven questions that relate to symptoms of prostatism. It has been shown to be valid for measuring severity of symptoms associated with BPH, as well as for measuring symptom response when men with BPH undergo treatment (Barry, Fowler, O'Leary, et al., 1992a, 1992b). The symptoms assessed, however, are not specific for BPH. Although other quantitative symptom-assessment tools can be used (Madsen and Iversen, 1983 ; Boyarsky, Jones, Paulson, et al., 1976), they have not been rigorously validated or made operational for patient self-administration.

Most patients seeking treatment for BPH do so because of bothersome symptoms that affect the quality of their lives. Therefore, it is appropriate to attach major importance to the quantification of those symptoms, both to determine the severity of the disease and to document the response to therapy. Relief of symptoms is the single most important outcome to patients -- not flowrate, detrusor pressure, or urethral resistance factors.

The panel considers the objective documentation of a patient's symptom level the most essential part of its recommendations for the diagnosis, evaluation, treatment planning, and followup of patients with prostatism. The AUA Symptom Index is recommended by the panel as the best available instrument. However, the panel emphasizes that optimal treatment decisions for individual patients will also need to take into account how a given level of symptoms affects each patient's quality of life (bothersomeness).

## Optional Tests

The tests below are optional, following the basic evaluation, for men presenting with prostatism:

- Urinary flowrate recording (uroflowmetry).
- Measurement of postvoid residual urine (PVR).
- Pressure-flow studies.
- Urethrocystoscopy, but only during later evaluation if invasive treatment is being planned. Urethrocystoscopy is recommended if men with prostatism have a history of: microscopic or gross hematuria, urethral stricture (or risk factors such as history of urethritis or urethral injury), bladder cancer, or prior lower urinary tract surgery (especially prior TURP).

## Tests Not Recommended

The following tests are not recommended in the evaluation of typical patients with symptoms of prostatism:

- Filling cystometry (cystometrography or CMG).
- Urethrocystoscopy, not recommended in initial evaluation to determine the need for treatment.
- Imaging of the upper urinary tract by ultrasonography or intravenous urography, not recommended unless patients have one or more of the following: hematuria, urinary tract infection, renal insufficiency, history of urolithiasis, history of urinary tract surgery.