# Investigational Treatment Strategies

A variety of patient, market, and economic forces are driving the development of new BPH treatment modalities. Several of these new technologies, such as laser prostatectomy and balloon dilation, have made their way into the private practice environment without adequate evaluation of benefits and risks in appropriately designed trials. The FDA has recognized this problem and has now developed general guidelines for BPH device technologies that require controlled trials and standardized collection of data.

Some feel that this increasing regulatory stringency will hamper the development of new technologies. Yet there is no evidence that the new FDA guidelines have hampered new technology development. Moreover, BPH is rarely a life-threatening disease. Some believe that accelerated testing and review, which may be appropriate for anticancer and anti-AIDS therapies, may be less important for a quality-of-life disease like BPH, which can be effectively managed with existing therapies.

At the same time, there is ample justification for further research and development in the field. Some of the newer invasive technologies may achieve surgical-level improvements with less risk, but data for any of the new invasive technologies are currently insufficient to provide a true analysis of benefits and risks. More information is needed to support the informed patient decisionmaking that is the focus of this Clinical Practice Guideline. From the standpoint of the explicit BPH guideline process, a new technology is investigational until the evidence of benefits and risks, from published controlled clinical trials, is sufficient to permit an adequate estimate of treatment outcomes, which can then be communicated to the patient in a form that allows him to make an informed decision.

## Evaluation of New Technologies

Ideally, new BPH treatments should be evaluated in four stages:

- Preclinical studies to demonstrate efficacy and safety in animal models.
- Initial human studies, primarily to demonstrate safety and dose-response relationships.
- Demonstration of efficacy and safety in randomized, placebo- (or sham-) controlled, multicentered clinical trials of 1-year duration.
- Long-term outcomes studies designed to determine the effectiveness of the treatment, relative to standard treatments such as watchful waiting and TURP.

During the 1-year clinical trials designed to determine treatment efficacy, the outcomes of primary concern should be reduction in AUA symptom score, improvement in maximal urinary flowrate (Qmax), and possible adverse outcomes including effects on sexual function and continence. In abstracts and journal reports, outcome data should be reported in absolute numbers as well as percent improvement. In the later stages of technology assessment designed to test treatment effectiveness, symptom score improvement, effects on quality of life, treatment failure, progression to surgery, and cost should be the outcomes of primary concern. Given the importance of this type of technology assessment in determining cost-effectiveness of treatment, it is reasonable to expect payers (State, and Federal governments and insurance carriers) to share in the cost of evaluation.

Decisions concerning FDA approval to market new technology are appropriately focused on demonstration of efficacy ascertained in classic clinical trials. By contrast, demonstrations of effectiveness in routine practice and of cost-effectiveness need to come from technology assessment trials.

The BPH Guideline Panel has reviewed the published data currently available on a variety of new BPH treatments. Following is a summary overview of the rationale and status of these new treatments.

### Laser Prostatectomy

Laser energy has been utilized to destroy neoplastic tissue in a variety of organ systems, and neodymium yttrium aluminum garnet (YAG) laser technology has been used successfully to treat BPH. Initial experiences with bare laser fibers were disappointing, primarily because of their inability to penetrate deeply into prostatic tissue. The first major advance was the development of right-angle laser fibers that permit delivery of the energy at right angles to the fiber.

Right-angle YAG fibers can be guided under direct vision through a cystoscope or by transurethral ultrasound imaging. Investigators in the field do not agree on the optimal technique of energy delivery. Some of the laser technologies produce coagulation necrosis with delayed slough of tissue. Other lasers result in immediate tissue vaporization and ablation. The relative benefits and risks of these two approaches have not been adequately defined. Moreover, the relative advantages of visual guidance compared with ultrasound guidance of the laser fiber itself are uncertain.

Current evidence from short-term, noncontrolled trials suggests that laser prostatectomy produces significant symptom score improvement. Flowrate improvements, however, are not equivalent to those produced by TURP. Blood loss is clearly less with laser prostatectomy, and TURP syndrome is totally avoided; but patients tend to require longer periods of catheterization and have more temporary pain on urination than seen following TURP.

The true benefits and risks of laser prostatectomy must be defined in clinical trials that compare the technology directly with TURP. Long-term trials will also be needed to determine retreatment rates and cost-effectiveness.

### Hyperthermia and Thermal Therapy

Hyperthermia and thermal therapy of the prostate utilize electromagnetic waves with a frequency greater than 200 MHz (microwaves) to induce heating and presumably tissue damage. Tissue penetration depends on the frequency of the electromagnetic waves. The lower the frequency, the deeper is tissue penetration. Although microwave has been the primary modality utilized to heat prostatic tissue, recently radiofrequency and high-intensity ultrasound have been used for the same purpose.

To destroy normal tissue, a temperature in excess of 45 degreesC is probably required. The administration of temperatures above 45 degreesC is referred to as thermal therapy, and treatment to temperatures below 45 degreesC is referred to as hyperthermia. Temperatures in excess of 45 to 50 degrees C are known in animal models to produce tissue coagulation, but temperatures in the hyperthermia range have no clearly demonstrable prostatic effects. The principle of hyperthermia, that neoplastic cells are more sensitive to slight elevations of temperature than normal cells (which has been validated in cancer model systems) may not be operational in the benign hyperplastic prostate. Thus, the rationale for hyperthermia in the treatment of BPH remains hypothetical. Thermal therapy, by contrast, has the potential to produce actual tissue destruction.

Several clinical trials have been performed with both transurethral and transrectal hyperthermia. The results are mixed, and there is no consensus on whether hyperthermia has an effect in the prostate above that seen with sham treatment. Recognizing the limitations of hyperthermia, most investigators now utilize higher temperatures.

Several industrially sponsored trials on transurethral thermal therapy are ongoing in different countries, including the United States. Although preliminary, these initial studies suggest that transurethral thermal therapy, at least in the short term, produces symptom and flowrate improvement superior to sham (placebo) treatment. However, the magnitude of improvement is at best intermediate between medical therapy and surgery. In addition, a significant number of patients develop urinary retention after the procedure, requiring short-term catheterization. Finally, patients may have urinary discomfort for some period of time after the procedure. Investigators are now altering the treatment times and energy levels for thermal therapy to try to achieve improvements closer to that seen with surgery.

Thermal therapy is a rational treatment approach warranting further investigation. Long-term, controlled trials are required to determine the effectiveness of this approach.

### Prostatic Stents

Prostatic stents are metal devices that can be placed into the prostatic urethra, under either endoscopic or fluoroscopic control. The two stents currently under evaluation are made of biologically inert metal. When expanded into the prostatic urethra, they partially relieve the obstruction from the surrounding prostatic tissue. Over a period of a few weeks to a few months, the stents are covered with normal transitional cell epithelium. To date, most of the patients treated with prostatic stents have been in urinary retention. A majority of patients have been able to void successfully after placement of the stent.

There have, however, been problems with encrustation (calcification) of the stents, as well as some degree of perineal pain and discomfort on urination. Clinical trials of prostatic stents are still ongoing. Long-term efficacy and safety remain to be demonstrated. More important, it remains unclear whether prostatic stents have applications in men with symptomatic BPH who have not developed urinary retention.

## New Medical Therapies

### Androgen Receptor Antagonist Therapy

Currently being evaluated for the treatment of BPH are several drugs that block the action of androgens at the level of the prostatic cell by inhibiting the binding of testosterone and dihydrotestosterone to the androgen receptor in the nucleus of the cell. In preliminary trials, androgen receptor antagonists have demonstrated some degree of prostatic involution, with improvement in both symptoms and urinary flowrates. However, the toxicity of androgen receptor antagonists is significant. Approximately one-half of patients develop breast tenderness or gynecomastia. In addition, one androgen receptor antagonist has a significant incidence of hepatotoxicity. Androgen blockade produces an increase in serum luteinizing hormone levels that leads to further testosterone production in the testes. Some of this increased testosterone is aromatized into estrogen. Testosterone-estrogen ratios in the breast are thus significantly altered. If androgen receptor antagonists could be developed that do not elevate serum gonadotropins, they may be attractive forms of therapy.

### 5-Alpha Reductase Inhibition

Several new types of 5-alpha reductase inhibitors are undergoing testing. There are presently no data to suggest that any of the new inhibitors will be substantially better or safer than finasteride.

### Alpha Blocker Therapy

Several long-term clinical trials are now in progress to assess the efficacy of alpha blocker therapy over placebo. Published trials are limited to 3-6 months of therapy. The results of the longer term trials will be important to determine whether treatment response deteriorates with time, and to determine actual probability of treatment failure and cost-effectiveness.

It is now recognized that the primary adrenergic receptor in the prostate is the alpha 1C subtype. This observation may well catalyze the development of alpha 1C antagonists that may be more selective for prostatic smooth muscle relaxation and that would presumably have fewer peripheral side effects such as asthenia and orthostatic hypotension.

### Aromatase Inhibitor Therapy

In the canine model of BPH, estrogens are synergistic with androgens in the production of experimental BPH. This observation has led to the hypothesis that estrogens are important in both the initiation and maintenance of human BPH. Small levels of circulating estrogen in men are derived from conversion of testosterone to estrogen in peripheral tissue (primarily fat). This testosterone-to-estrogen conversion is catalyzed by the enzyme aromatase. Several inhibitors of the aromatase enzyme have been developed and tested in BPH clinical trials. No results have been published to date from these ongoing clinical trials. Aromatase inhibitor therapy is known to produce significant increases in serum testosterone levels. Many investigators are concerned that the beneficial effect of lowering of estrogen within the prostate may be tempered by stimulation of androgen-dependent growth processes.

### Combination Therapy

Given the independent mechanisms of action of alpha receptor antagonists and hormone withdrawal therapies, combinations of these two approaches are rational treatments to consider. Currently, the Department of Veterans Affairs is conducting a large, multicenter, randomized clinical trial to determine the efficacy of finasteride plus terazosin, compared with single agents. Until the results of this trial are available for review, combination therapy cannot be recommended for routine practice.