# Treatment Preference Analysis

The degree to which BPH patients are bothered by urinary symptoms varies dramatically among individual patients with the same degree of symptoms. However, patients with mild symptoms prefer watchful waiting. There is a wide range of preference in patients with moderate-to-severe symptoms. Therefore, the "best" treatment from the patient's viewpoint may be different from the most efficacious treatment from the physician's viewpoint. Patients may prefer less effective therapy if it also has less risk.

BPH affects the quality rather than the quantity of life. Most prostatectomies are performed to relieve symptoms (Holtgrewe, Mebust, Dowd, et al., 1989). The degree to which a patient's symptoms bother him is primarily what will determine his perceived need for therapy. This factor, together with his view of the relative benefits and harms of each treatment option, will also help determine his therapeutic preference.

Despite gaps in available data for BPH therapeutic outcomes and their relative benefits and harms, the panel was able to ascertain whether a given therapy has a net benefit. However, patients' views may differ from those of panel members regarding the desirability of specific health outcomes. Patients may also weigh the balance of harms and benefits differently. For example, to a urologist the risk of post-TURP mortality or of urinary incontinence may be acceptable in view of the large expected magnitude of symptom reduction from the procedure -- whereas to a patient averse to risk, these potential harms may be unacceptable. The patient may seek a less effective treatment option because it has lower risk. The decision is based as much on personal values as on scientific evidence.

To gauge the range of personal preferences regarding benefits and harms of BPH treatment strategies, two types of preference analyses were performed: proxy judge analysis and patient preference analysis. These analyses were performed prior to FDA approval for the release of finasteride.

## Proxy Judge Analysis

Thirty-eight physicians (not urologists) and PhD-level medical researchers over the age of 60 served as "proxy" patients for determining the feasibility of a patient-preference analysis using the Balance Sheet of benefits and harms (Attachment B) as the central focus. In the initial exercise, proxy patients were given a set of cards listing direct outcomes such as incontinence or symptom improvement. The proxy patients arranged these outcomes in order of importance. As shown in Table 29, symptom improvement was the most important outcome followed by urinary incontinence and other immediate treatment complications. Retrograde ejaculation, blood transfusion, recovery time, and cost were considered less important.

Table 29. Outcomes as ranked by 38 proxy judges, listed in descending order of importance [1]

Outcomes | Rank
Improvement of symptoms | 1.9
Incontinence | 3.8
Immediate surgical complications | 5.9
Operative mortality (>90 days) | 6.1
Complications requiring surgery | 6.7
Impotence | 7.0
Adverse effects of drug therapy | 7.2
Treatment for recurrent/persistent BPH | 7.6
Duration of recovery time | 8.4
Pain due to treatment | 9.0
Loss of work time | 9.5
Duration of hospital stay | 9.8
Cost of treatment | 10.0
Requirement for blood transfusion | 10.4
Retrograde ejaculation | 10.5

[1] Rank order determined by dividing the total of all rankings by the number of respondents.

Each proxy patient was next asked to read four scenarios describing patients with mild symptoms (AUA symptom score <=7), moderate symptoms (AUA symptom score 8 to 19), and severe symptoms (AUA symptom score >=20) and a patient in refractory urinary retention. Each proxy patient was given a balance sheet detailing the anticipated benefits and harms from each treatment, along with a brief description of the treatment. Each proxy was asked to envision himself as an actual patient within the described medical scenario and to make a decision concerning the most desirable treatment option. The decisions are summarized in Figure 11

Figure 11. Treatment choices of proxy judges, stratified by BPH symptom severity

Almost 70 percent of the proxy judges elected watchful waiting as their treatment if they had mild symptoms. In contrast, more than 70 percent of the judges elected TURP as their treatment if they had severe symptoms or urinary retention. Proxy patients with moderate symptoms elected a wide range of preferences.

Proxy patients with mild symptoms felt that the risks of active therapy outweigh its benefits. Proxy patients with severe symptoms or urinary retention believed the benefits of TURP outweigh the harms. The range of treatment preferences expressed for the moderate symptom scenario reflects variations in the way that the individual judges viewed the risk-to-benefit ratio.

## Patient Preference Analysis

To evaluate the preferences of actual patients with symptomatic BPH, the panel developed a booklet that described BPH, contained a simplified version of the balance sheet, and listed the important outcomes of four treatment modalities: watchful waiting, alpha blocker therapy, balloon dilation, and surgery (TURP). Data on finasteride were not available at the time of the preference analysis.

TURP was the only surgical treatment described for the patient preference analysis for two reasons. First, it was clear from the proxy patient analysis that even nonurological physicians and medical researchers could not adequately discriminate between the relative benefits and harms of the various surgical procedures. Second, the panel concluded that the specific choice of a surgical technique, which is often a matter of the technical feasibility of each procedure, should be made primarily by surgeons rather than patients.

Fifty-three BPH patients visiting the offices of urologic panel members were given the self-administered AUA Symptom Index questionnaire (see chapter 4) so that their responses could be analyzed by symptom category. Based on the answers given, 12 of the 53 patients were categorized as having mild symptoms, 26 as having moderate symptoms, and 15 as having severe symptoms. Patients with refractory urinary retention were not evaluated.

The respondents completed a questionnaire that asked them to select a personal treatment option based upon their review of the information presented. Figure 12 summarizes the choices of the 40 patients who responded to this question.

Figure 12. Treatment choices of patients, stratified by BPH symptom severity

Similar to the proxy patient group, the majority of patients with mild symptoms (almost 80 percent) preferred watchful waiting. In contrast to the proxy patient group, however, some patients with severe symptoms were still willing to consider watchful waiting as a treatment option, although TURP was viewed as a desirable treatment by approximately one-half the patients. Once again, the patients with moderate symptoms displayed a wide range of preferences, although many still preferred watchful waiting.

Patients were also asked whether they had a positive, neutral, or negative view of each treatment option. The results of this question, stratified by symptom severity, are summarized in Figure 13. Again, a very positive view of watchful waiting emerges in the case of patients with mild symptoms, whereas this option is viewed less favorably by patients with severe symptoms. Attitudes were highly variable for patients in the moderate symptom group.

Figure 13. View of treatment options by patients, stratified by BPH symptom sever

## Conclusions

The small sample sizes in the proxy patient and patient preference analyses prevent a full assessment of patient views; for example, views concerning the relative desirability of medical therapy or balloon dilation therapy. This exercise was undertaken primarily to determine whether there was diversity of preferences or a high degree of unanimity among patients with similar symptoms. The data, however, should not be used to determine the relative desirability of any specific treatment option in patients with moderate symptoms.

Although limited in scope, the analysis does provide some clear messages. For one, patients with mild symptoms of prostatism prefer watchful waiting. For another, patients with severe symptoms are more likely to elect surgical intervention. Yet, a number of patients with severe symptoms will choose not to have a surgical intervention, either because they are not bothered sufficiently by their symptoms or because they view the risk of surgery as unacceptable. Patients with moderate symptoms, the majority of patients presenting for an initial evaluation, display a wide range of preferences. The variations in both the group with moderate symptoms and the group with severe symptoms are likely due to individual patient preferences, the degree of bothersomeness, and how each individual views the risks associated with therapy.

Considering the wide variations in patient preferences indicated by the analyses, the panel concluded that patients' choices need to be elicited and that patients and health care providers should share the decisionmaking regarding treatment strategy.