# Direct Treatment Outcomes— Mortality

## Perioperative Mortality

Combined analysis of published data results in an estimate of the mean probability for perioperative mortality of 1.52 percent for TURP, determined primarily by large studies based on claims data; this risk is higher than what many urologists would predict and is higher than that reflected in surgical case series alone. TUIP clearly has a lower mortality than TURP.

Perioperative mortality following intervention for BPH is an outcome of considerable concern to patients. For this report, perioperative mortality is defined as death within 90 days after a procedure. This timeframe was selected because most studies report 3-month mortality data. Perioperative mortality is captured in the panel's BPH outcome data base for all surgical treatment options (Table 23).

Table 23. Combined analysis of perioperative mortality

Treatment Modalities | Mortality >= 90 days following intervention[1]
Treatment Modalities | N[2] | Weighted average[3] | Mean[4] | 90% CI[5]
Open surgery | 25,022 | 2.6% | 2.4% | 1.0-4.6%
TUIP | 1,133 | 0.4% | 0.7% | 0.2-1.5%
TURP | 56,081 | 2.0% | 1.5% | 0.5-3.3%
Balloon dilation | 107 | 2.9% | 3.5% | 0.7-9.8%

1. Followup times variable.

2. Number of patients in treatment arm.

3. Weighted average of outcome.

4. Mean (50%) probability of outcome to occur.

5. Ninety-percent confidence interval for probability of outcome to occur.

Note: TUIP = transurethral incision of the prostate. TURP = transurethral resection of the prostate.

### Mortality for 67-Year-Old Men

The average age for surgical treatment for BPH is 67 years. At age 67, the risk of death within the next 3 months is 0.8 percent (U.S. Decennial Life Tables, 1990). If all surgical series correctly identified any patient dying during a followup period of 3 months, it would appear that causes not directly related to the treatment of BPH account for about 0.8 percent of the estimated probability of dying within this time period. However, followup is not complete in most surgical series. In addition, there are no data to determine whether men treated for BPH are, on average, healthier (with a lower risk of death) or sicker (with a higher risk of death) than all men represented in the life tables. It is therefore not possible to assume that 0.8 percent mortality can be subtracted from the estimated mean probability of dying within 3 months after surgery, so as to derive the probability of dying directly due to the treatment for BPH. For information purposes in the Balance Sheet (Attachment B), the probability of dying within the next 3 months for a 67-year-old man is listed as 0.8 percent in the columns for alpha blockers and watchful waiting.

### Perioperative Mortality: Open Surgery

Early postoperative mortality is reported in 21 studies of treatment outcomes following open surgical removal of the prostate. The total number of patients included is 25,022. Based on the large number of patients available for this analysis, and the finding that reported incidences range only from 0 percent to a maximum of 5 percent, the range of uncertainty is relatively narrow. The risk of early postprostatectomy death is 2.4 percent (90-percent CI 1.0-4.6 percent). The risk appears to be higher for suprapubic than for retropubic enucleation of the prostate, although this finding may not be due to differences between the two operations.

### Perioperative Mortality: TURP

Seventeen studies report on perioperative mortality following TURP (Figure 9). The total number of patients included is 56,081. The majority of these patients are included in a report that examines mortality following TURP in three geographic areas (Roos, Wennberg, Malenka, et al., 1989). The data presented allow for each of the data sets to be examined and analyzed separately. They represent the outcomes following prostatectomy in Denmark; Manitoba, Canada; and the Oxford region of England. Including all studies, the incidence of early postoperative mortality after TURP ranges from 0 percent to 4.38 percent. Overall, the weighted average probability is 2.01 percent.

Figure 9. Probability of perioperative mortality following TURP

The study contributing the most patients to this analysis reports an overall combined probability for early postoperative deaths of 2.91 percent (Roos, Wennberg, Malenka, et al., 1989). All other studies reporting perioperative mortality following TURP result in a probability of 1.18 percent. Because of the large number of patients involved in the study by Roos, Wennberg, Malenka, et al. (1989), the overall combined probability results in a mean estimate of 1.5 percent (90-percent CI 0.5-3.3 percent).

### Perioperative Mortality: Balloon Dilation

The highest risk for treatment mortality exists for patients undergoing balloon dilation: probability 3.5 percent (90-percent CI 0.7-9.8 percent). However, there is a wide range of uncertainty as shown in the probability curve (Figure 10). The analysis includes many early balloon dilation studies, with patients being treated who were at too great a risk for TURP. This bias obviously results in a high mortality estimate. In the panel's judgment, the perioperative mortality for balloon dilation in comparable-risk patients is lower than for TURP.

Figure 10. Probability of perioperative mortality following: (1) balloon dilation, (2) open surgery—all modalities, (3) TUIP, and (4) TURP

### Comparison of Treatment Modalities

The combined Bayesian analysis reveals a mean probability for perioperative mortality of 2.35 percent for open surgery and of 1.52 percent for TURP (Figure 10). The probability distributions, however, do overlap considerably. The mortality estimates are not significantly different. The lowest risk among the surgical options is estimated for patients undergoing TUIP, and the range of uncertainty for this particular modality is narrow. There are no reports in the literature of mortality (determined to be directly drug related) from pharmacologic treatment of BPH.

### Perioperative Mortality: Conclusions

There are many confounding factors that prevent firm conclusions from being drawn regarding mortality following BPH surgery. Patient selection bias may influence relative mortality rates more than true differences in the risks of TURP or open prostatectomy. For example, statistically, the average age of the patients reported does not differ significantly between open prostatectomy and TURP. Whether the patients treated by open surgical enucleation of the prostate represent a population that is in general less healthy is impossible to determine from this retrospective analysis of the literature. Patients selected for open surgery rather than TURP may be a healthier subpopulation. This would lead to the conclusion that open prostatectomy is associated with a higher early postoperative mortality rate. For TUIP, however, the mortality risk is clearly lower than for the other surgical interventions.

## Delayed Mortality

The relative risk of delayed mortality following TURP may be greater than the relative risk of delayed mortality following open surgery for BPH, based on retrospective, claims-based analysis of men undergoing both procedures. No study to date offers a convincing explanation for this phenomenon. However, one recent study found no increased risk for TURP compared with open surgery after careful adjustment for comorbidity. Although TURP is associated with long-term mortality, relative to open prostatectomy, unmeasured comorbidity among TURP patients seems the most likely explanation for the association. Whether TURP, in and of itself, actually causes delayed mortality remains controversial.

Differences in delayed mortality between TURP and open prostatectomy of up to 10 years after surgery have been reported (Roos, Wennberg, Malenka, et al., 1989). The panel's data base used for the analysis of outcomes such as symptom improvement does not provide sufficient data to resolve the question of what accounts for the differences because most investigators focus on immediate results following treatment rather than on long-term followup.

Explanations offered for the differences found in delayed mortality between TURP and open prostatectomy include differences in patient comorbidities as well as patient selection bias. The relative risk (RR) ratios for 5-year mortality following TURP as compared with open surgery, from four studies which include some attempt to adjust for comorbidity, were combined using the hierarchical Bayes' formula (Table 24.

Table 24. Relative risk and 95% CI of 5-year mortality following TURP, as compared with open surgery, for four individual studies and combined analysis

Reference | Source and adjustments | RR | 95% CI
Concato, Horwitz, Feinstein, et al., 1992 | Yale-New Haven Hospital; chart-review data; adjustments: comorbidity (Kaplan-Feinstein), age | 0.91 | 0.47-1.76
Folmer Andersen, Bronnum-Hansen, Sejr, et al., 1990 | Male Danish population; data-base data; adjustments: comorbidity, age | 1.19 | 1.15-1.24
Roos, Wennberg, Malenka, et al., 1989 | Subset from University Hospital; data-base data; adjustments: comorbidity | 1.45 | 1.15-1.83
Malenka, Roos, Fisher, et al., 1990 | Subset from Health Science Center, Winnipeg, Canada; chart-review data; adjustments: comorbidity (Charlson), age | 1.48 | 1.09-2.01
Combined analysis | Hierarchical Bayes | 1.26 | 0.99-1.59

Note: CI = confidence interval, RR = relative risk, TURP = transurethral resection of the prostate.

Roos, Wennberg, Malenka, et al. (1989) reported mortality up to 8 years following TURP or open surgery in three geographical areas (Denmark; the Oxford region of England; and Manitoba, Canada). The Manitoba data were adjusted for claims-based comorbidity data such as concomitant diagnoses and prior hospitalizations. Table 25 shows the age-adjusted cumulative risk of death per 100 patients after TURP or open surgery, according to geographic location.

Table 25. Age-adjusted cumulative risk of death (per 100) after surgery according to location and type of surgery

Location and type of surgery | Time
Location and type of surgery | 90 days | 1 year | 5 years | 8 years
Denmark
TURP: 27,911 patients[1] | 2.47 | 7.55 | 31.05 | 46.50
Open: 8,782 patients[1] | 2.67 | 5.76 | 25.49 | 39.78
Relative risk | 0.93 | 1.31 | 1.22 | 1.17
Manitoba
TURP: 8,995 patients[1] | 1.73 | 5.97 | 25.37 | 39.25
Open: 3,095 patients[1] | 1.57 | 4.18 | 21.14 | 33.53
Relative risk | 1.10 | 1.43 | 1.20 | 1.17
Oxford
TURP: 2,171 patients[1] | 4.39 | 10.32 | 35.42 | 49.49
Open: 3,113 patients[1] | 3.21 | 7.64 | 26.45 | 38.42
Relative risk | 1.37 | 1.35 | 1.34 | 1.29

[1] Number of patients in treatment arm.

Note: TURP = transurethral resection of the prostate.

A separate analysis of patients from the University of Manitoba teaching hospital revealed that the RR of dying within 5 years following TURP, compared with open surgery, was 1.45 (95-percent CI 1.15-1.84 percent) before and after age and comorbidity adjustment. This finding of a higher RR of dying following TURP remained unchanged when the data were adjusted using a variety of comorbidity indicators -- such as general health status, age, prior diagnosis of cancer, nursing home resident, on digitalis, and high-risk diagnosis -- taken both from claims data and from a separate, concurrent prospective study of anesthetic risk. An analysis of the causes of death showed that the excess mortality following TURP was mainly due to cardiovascular causes, especially acute myocardial infarction.

Other studies have been conducted. One by Malenka, Roos, Fisher, et al. (1990) reevaluated a subset of the patient population that had previously been reported by Roos and Ramsey (1987) and Roos, Wennberg, Malenka, et al. (1989). The purpose was to identify whether differences in case mix, unidentified by data previously available, explained the increased mortality following TURP. To this end, a chart review was performed by six trained abstracters, blinded to the purpose of the study, at the Manitoba Health Science Centre, Winnipeg, Canada.

The chart review included 485 patients who underwent prostatectomy between 1974 and 1980 (236 open surgery, and 249 TURP). In this subset, the crude RR of dying in the 5 years following TURP as compared with open surgery was 1.58 (95-percent CI 1.07-2.33 percent). This relative risk decreased, after controlling for patient age, to a RR of 1.48 (95-percent CI 1.09-2.01 percent). Further adjustment, using comorbidity data from the chart review including the Charlson Weighted Comorbidity Index (Charlson, Pompei, Ales, et al., 1987) and the Karnovsky score, did not change the results significantly.

Concato, Horwitz, Feinstein, et al. (1992) conducted a retrospective cohort study at Yale-New Haven Hospital, involving men undergoing TURP (n = 126) or open prostatectomy (n = 126) for BPH from 1979 through 1981, and assessed 5-year mortality adjusted for age and severity of comorbidity at time of surgery. Comorbidity was measured by the Kaplan-Feinstein and Charlson methods (Kaplan, and Feinstein, 1974 ; Charlson, Pompei, Ales, et al., 1987). At 5 years following surgery, 17.5 percent of patients had died after TURP, compared with 13.5 percent after open surgery. However, a comparison using the Kaplan-Feinstein comorbidity grade revealed a higher proportion of TURP patients having more severe comorbidity grades. The adjusted estimate of the RR was 0.91, albeit with a broad confidence interval given the small size of the study.

A group of Danish investigators (Folmer Andersen, Bro nnum-Hansen, Sejr, et al., 1990) studied survival by linking hospital discharge data with mortality data for the entire male population of Denmark, 1977-85. For a maximum of 10.5 years (minimum 2 years), 38,067 patients were followed. Of these patients, 28,991 had a TURP and 9,076 had open surgery. After adjustment for age only, the RR for dying within 10.5 years, TURP compared with open surgery, was 1.24 (95-percent CI 1.20-1.29 percent). After adjusting for age and comorbidity, the RR for TURP compared with open surgery was 1.19 (95-percent CI 1.15-1.24 percent) for all patients.

Sidney, Quesenberry, Sadler, et al. (1992) assessed the incidence of reoperation and mortality after TURP and open prostatectomy in 8,219 men in the Kaiser Permanente Medical Care Program, Northern California Region. The vast majority (7,771 of 8,219, or 94.5 percent) received TURP. Of the open prostatectomies, 211 (49 percent) were done suprapubically and 138 (31 percent), retropubically. In 89 (20 percent), the technique used was not known. The age-adjusted RR of dying, TURP compared with open surgery, was most pronounced during the first 5 years postsurgery (RR 1.8, 95-percent CI 1.3-2.5 percent). It declined to 1.1 (95 percent CI 0.8-1.6 percent) for deaths after the first 5 years. The authors did not attempt a formal adjustment for comorbidity in this population. The literature includes additional studies that attempt to explain differences in delayed mortality for TURP and open prostatectomy.