# Direct Treatment Outcomes— Need for Retreatment

Open prostatectomy appears to have the lowest probability of treatment failure and/or need for retreatment within 5 years. For open prostatectomy and for TURP and TUIP, the probability of failure requiring retreatment remains constant throughout at least 5 to 8 years of followup. Balloon dilation and watchful waiting demonstrate a high failure rate the first year and a subsequent decrease in the failure rate throughout the remainder of the followup to 5 years. Surgical intervention by any technique has a lower retreatment rate than alpha blocker, finasteride, balloon dilation, and watchful waiting modalities. Among the nonsurgical modalities, there is no statistically significant difference in probabilities of treatment failure.

## Overview

The probability of retreatment is an outcome of major importance to patients. Moreover, the likelihood that patients initially treated nonsurgically will eventually need surgery is a major determinant of the cost-effectiveness of therapy. The retreatment (reoperation) rate following TURP has been reasonably well defined as 5-15 percent at 8 years. The retreatment rate for open surgery is lower than for TURP. TUIP and TURP retreatment rates are similar (see Table 22).

Table 22. Five-year projected treatment failure rates

Treatment modalities | High estimate | Low estimate
Watchful waiting | 38% (90% CI 15-65%)[1]
Alpha blocker | 39% (90% CI 23-70%)[2] | 13% (90% CI 4-31%)[1]
Finasteride | 27% (90% CI 25-29%)[2] | 10% (90% CI 9-12%)[1]
Balloon dilation | 32% (90% CI 15-52%)[1]
TUIP | 9% (90% CI 1-28%)[3]
TURP | 10% (90% CI 9-11%)[3]
Open surgery | 2% (90% CI 1-4%)[3]

1. Reported initial failure rate, with subsequent period up to 5 years assumed to have 20 percent of the initial failure rate, modeled after the study by Craigen, Hickling, Saunders, et al. (1969).

2. Reported initial failure rate assumed to be linear up to 5 years.

3. Single point estimates and confidence intervals (CIs), devised from large clinical series out to and past 5 years.

Note: TUIP = transurethral incision of the prostate. TURP = transurethral resection of the prostate.

For nonsurgical therapies, with few long-term data available, the panel utilized an approach to analyzing failure rates that assumes a best and worst case scenario. In the best case (low estimate), failure rates are assumed to level off after the first year. In the worst case (high estimate), they are assumed to continue at a fairly constant rate to 5 years.

The retreatment rate for balloon dilation is high in the few long-term studies that have been published and is not markedly different from the failure rate for watchful waiting. The long-term failure rates of medical therapy, and more important the probability of a patient's going on to surgery, are not known. This limits any discussion of the cost-effectiveness of medical therapy.

Long-term randomized studies of watchful waiting, surgery, and alternative therapies will be required to determine the effects of particular BPH therapies on cost of treatment.

Treatment failure and retreatment rates are not commonly reported in the BPH literature despite the crucial relationship of these outcomes to treatment cost-effectiveness. Only a limited number of studies on retreatment rates are available, and their quality varies greatly. Several studies provide data on patients followed under a watchful waiting strategy and their need for later prostatectomy. However, these studies are generally older, and the documentation of indications for surgery is not always clear. Also, because of wide variations in prostatectomy rates in the United States and abroad (McPherson, Wennberg, Hovind, et al., 1982), the usefulness of surgery as a proxy outcome for "disease progression" is questionable.

No studies clearly document the treatment failure rate and the need for retreatment with use of alpha receptor blocking agents or finasteride. Several studies report failure rates and retreatment data for balloon dilation and TUIP over less than a 5-year followup period. For both treatments, however, there is at least one study available to permit an estimation of the 5-year treatment failure and retreatment rates. Retreatment rates following TURP and open surgery for BPH have recently been analyzed and published in several large-scale studies. These studies are mainly based on insurance claims and other administrative data bases.

## Factors Influencing Reported Rates

Factors significantly influencing the reported failure and retreatment rates include the following: patient selection, accuracy and completeness of followup, and accuracy of retreatment data reported.

### Patient Selection

Reports on treatment failure and retreatment rates vary considerably depending on the patient population initially selected for treatment, thereby introducing the risk of selection bias. After other options were carefully considered, it was decided to report retreatment/failure rates based on the assumption that patients within each treatment group were similar. This decision was made in order to permit utilization and analysis of the existing data.

### Accuracy and Completeness of Followup

The duration of followup is often difficult to assess in published reports of treatment outcomes. Because there is no accurate method to correct for incompleteness of followup, the panel elected to take data at face value and not attempt to adjust the results for possible underreporting of failures.

### Accuracy of Retreatment Data Reported

The reported data are not always clear regarding patient choices of retreatment after treatment failure and can lead to underestimation or overestimation of retreatment rates. In the case of watchful waiting studies, patients reported as treatment failures could be assumed to undergo surgical treatment for BPH either to relieve symptoms or because of urinary retention. In the case of alpha blocker reports, however, this assumption may not be accurate. According to data reviewed by the panel, all patients who dropped out of alpha blocker and finasteride studies because of lack of efficacy may not have undergone surgery. Some simply stopped taking the drug and adopted watchful waiting programs. Thus, converting treatment failure rates into rates of patients undergoing surgery might overestimate the number of patients going on to surgical treatment for BPH.

Those patients who failed balloon dilation are reported in most studies to have proceeded to TURP or open prostatectomy. Failure data and retreatment data are parallel for this modality. However, the large-scale claims data base studies reporting on retreatment rates following TURP or open prostatectomy might have overestimated to some degree the true retreatment for recurrent or persistent BPH. Up to 3.7 and 4.3 percent of patients following TURP and open prostatectomy are estimated to require surgical intervention for either bladder neck contracture or urethral stricture disease. It was impossible for the panel to accurately assess what fraction of patients in the claims data analysis underwent correction of such surgically induced complications, in contrast to those patients who truly needed retreatment for BPH. The data were accepted at face value with the understanding that the retreatment data, depending on the source, may be biased toward under- or overestimation.

## Treatment Modalities

### Watchful Waiting

As background to examining probabilities of failure for watchful waiting, it is useful to look at overall probabilities of prostatectomy. Several reports are available. Glynn, Campion, Bouchard, et al. (1985) reported the results of the VA Normative Aging Study, a cohort study of 2,036 volunteers in the Boston area. The probability, for men age 60 to 69 years, of undergoing a prostatectomy within 3.5 years following enrollment was 4.1 percent. The cumulative probability, for a 40-year-old man who lived to age 80, of having surgery for BPH was projected to be 29.2 percent. A prior clinical diagnosis of BPH in these unselected men was an important predictor of surgery (adjusted odds ratio 3.52, 95-percent CI 1.93-6.42 percent).

Sidney, Quesenberry, Sadler, et al. (1991) found, in an analysis of a data base from the Northern California Kaiser Permanente Medical Care Program, that urinary symptoms were predictive of prostatectomy, especially during the first 5 years of followup. The relative risk associated with having two obstructive symptoms, compared with having no obstructive symptoms, was 8.6 in the first 5 years (95-percent CI 6.2-11.9 percent).

Based on data from New Haven, Lytton, Emery, and Harvard (1968) estimated the probability of a 40-year-old man requiring an operation for BPH if he lived to 80 years of age as being approximately 10 percent. The risk for a man age 55 of undergoing prostate surgery before age 80 was 9.7 percent.

Based on data from the Baltimore Longitudinal Study of Aging, Arrighi, Guess, Metter, et al. (1990) calculated incidence rates of surgery for BPH per 1,000 men per year. The incidence rates increased steadily with age and were 14.2 per 1,000 for 60- to 64-year-old men and 36.8 per 1,000 for 80- to 84-year-old men.

These data demonstrate that the risk of a man undergoing prostatectomy increases not only with age, but also with the clinical diagnosis of BPH and the presence of symptoms associated with BPH.

The closest subpopulation in these studies comparable to a group of men with BPH being followed by a watchful waiting strategy is a group of men in the BLSA study who had clinical signs of BPH and enlarged prostates on digital rectal examination. For this group, the probability of subsequent surgery was 36.8 percent. Ball, Feneley, and Abrams (1981) followed, over 5 years, 107 patients with prostatism in whom prostatectomy was not clinically indicated at the time of initial presentation. Of these men, 10 required surgery for worsening of symptoms while 97 remained untreated. Two of these 10 men developed acute urinary retention over the 5-year followup. The retreatment probability in this group of men followed with observation (or watchful waiting) was 8.9 percent at 60 months.

Clarke (1937) followed a total of 93 men for a different length of followup and observed the percentage of patients that required prostatectomy during that time. In group 1 (doubtful diagnosis, n = 31 patients), followed for a mean duration of 5.3 years, the 60-month retreatment probability was 32.1 percent. In group 2 (definite diagnosis of BPH with small residual urine, and no complications, n = 36), the retreatment probability was 30 percent at 2.8 years. In group 3 (definite diagnosis with PVR over 100 mL or other complications, n = 15), the retreatment probability was 48.7 percent at 2.64 years. For group 4 (patients during or following acute or chronic urinary retention, n = 11), the retreatment probability after a followup of 2.64 years was 16.7 percent.

Useful information on watchful waiting comes from a study by Craigen, Hickling, Saunders, et al. (1969). Of 251 patients initially registered by 59 doctors in East Anglia, England, 123 presented with urinary symptoms indicative of prostatism but no retention. An analysis of those 123 patients revealed a retreatment probability (cumulative incidence of failure) of 55.8 percent at the end of the 5-year followup.

The risk of a patient's failing watchful waiting remains poorly defined. In general, the published watchful waiting case series describe the experience of men on surgical waiting lists. In this group of patients with severe symptoms, disease progression may be more rapid than in those men with mild-to-moderate symptoms. Certainly a failure rate of nearly 56 percent, as seen in the Craigen study, is higher than anticipated for men with only mild symptoms.

The Craigen study demonstrates a higher risk of failure during the first 1 to 2 years of followup, which subsequently decreases; that is, the incidence density decreases over time. Assuming similar decreases in the failure rates of BPH medical and surgical treatment over time, projection of long-term failure rates are problematic.

### Balloon Dilation

Several studies provide short-term data on balloon dilation failure rates up to 12 months (Shipman, and Akilie, 1967 ; Klein, Perez-Marrero, Bowers, et al., 1990 ; Goldenberg, Perez-Marrero, Lee, et al., 1990 ; Daughtry, Rodan, and Bean, 1990 ; Gill, Machan, Allison, et al., 1989). In a longer term report from Wasserman, Reddy, Zhang, et al. (1990), the followup extended to 3 years (mean followup 16.2 months). Seven of 73 patients were in urinary retention at the time of the procedure. According to the authors, prostatectomy was required at the most recent followup in 17 subjects. The rate of failure (incidence density) for year 1 was 20 of 588 (or 0.034) person-months. In year 2, two more patients required prostatectomy for an incidence density of 0.0065, and in year 3 one more patient required prostatectomy for an incidence density of 0.0086. Combining the data from years 2 and 3 produces an incidence density of 0.0071.

Assuming that the rate defined in the Wasserman study remains constant from year 2 to year 5, a cumulative incidence of treatment failure of 44 percent is calculated at 5 years. The failure rate for years 2 through 5 is approximately 20 percent of the failure rate during the first year of followup. Assuming that a similar dropoff in the failure rate occurs in all other series of patients treated by balloon dilation, and applying the incidence density derived from this article to the short-term balloon dilation studies, a cumulative incidence of failure at 5 years of 32 percent (90-percent CI 15-52 percent) can be projected for the remaining five studies analogous to the panel's projection of the watchful waiting studies, using the data provided by Craigen, Hickling, Saunders, et al. (1969) (see Table 22).

The assumption that the retreatment probability would follow in all other patient populations a similar pattern to that described by Wasserman, Reddy, Zhang, et al. (1990) can be challenged. Clearly, more long-term studies (3-5 years) of balloon dilation are required to accurately define failure and retreatment risk.

### Alpha Blockers

Failure and retreatment rates following therapy with alpha blocking agents are difficult to estimate. At the time of the panel's review, data on patients who dropped out of alpha blocker studies because of lack of efficacy were available mainly from two reports (Jardin, Bensadoun, Delauche-Cavallier, et al., 1991 ; Lepor, Henry, and Laddu, 1991). Each of these reports utilizes a specific alpha-1 receptor blocking agent (alfuzosin, and terazosin, respectively). Another source of data on terazosin is a report by Lepor and Knapp-Maloney (1991).

It cannot be determined whether the patients who dropped out because of lack of efficacy did in fact proceed to surgical treatment for BPH or to any other treatment for BPH. For the analysis presented in this section, the panel assumed that patients who failed to symptomatically improve under any given treatment protocol would proceed to another form of BPH therapy.

The report by Jardin, Bensadoun, Delauche-Cavallier, et al. (1991) is a randomized, controlled double-blind study examining the long-term efficacy and safety of alfuzosin in 251 patients treated with active drug, compared with 267 patients treated with placebo over 6 months. During this treatment period, 6.8 percent of patients dropped out of the alfuzosin group because of lack of efficacy, compared with 14.6 percent who dropped out of the placebo arm for the same reason. Of the alfuzosin-treated patients, 0.4 percent, compared with 2.6 percent of placebo-treated patients, went into urinary retention during the treatment period, presumably requiring surgical treatment.

Two terazosin studies are of particular interest in the report by Lepor, Henry, and Laddu (1991), which summarizes several studies. Designated MK-006 and MK-013, the two are comparable in their inclusion and exclusion criteria as well as in their study design (26-week treatment interval). The maximal dose of terazosin used was 10 mg per day. The MK-006 study enrolled 47 men and the MK-013 study 57 men, for a total of 104 men. There were three premature withdrawals in the MK-006 study because of worsening of BPH symptoms and none in the MK-013 study. For the two studies together, there was a 2.9-percent withdrawal rate because of worsening of BPH symptoms.

Extrapolating from 6-month data and assuming a steady dropout of patients because of lack of efficacy over 5 years or 60 months, the cumulative incidence of failure at 5 years would be 39 percent (90-percent CI 13-70 percent). The projected 5-year failure rate drops significantly to 13 percent (90-percent CI 4-31 percent) if the incidence density of failure past 6 months is decreased to resemble the 20 percent of initial failure rate seen in the watchful waiting study by Craigen, Hickling, Saunders, et al. (1969).

In the panel's opinion, the long-term failure rate of alpha blocker therapy is probably intermediate between the above two estimates (13 to 39 percent). Long-term trials are needed to definitively address the question.

Lepor and Knapp-Maloney (1991) reported on 45 men with BPH treated with a maximal dose of 5 mg of terazosin over 24 months. At 24 months, 47 percent remained on therapy. The remainder discontinued the drug for the following reasons: 13 percent for adverse events, 4 percent for recurrence of symptoms, 4 percent not returning for followup, 4 percent noncompliant, 4 percent for other reasons. The largest cohort, 22 percent, discontinued for a failure to maintain symptomatic improvement. (Percentages do not add to 100 percent because of rounding.)

### Finasteride

About 5 percent of all patients treated with finasteride dropped out of the 12-month phase III studies because of lack of therapeutic response or worsening of symptoms. Assuming that all the dropouts would seek alternative treatment options, this suggests a 5-percent 1-year failure or retreatment rate.

Fifty-three patients had prostate surgery while participating in all finasteride clinical studies; 18 of the 53 had urinary retention preoperatively. Other reasons for surgery included elective surgery, lack of improvement, worsening condition, no reason specified, and prostate cancer. In the phase III studies, 11 of 1,000 active-drug-treated patients had surgery within 12 months (5 for urinary retention, 6 for other reasons), while 8 of 555 patients on placebo had surgery (2 for urinary retention, and 6 for other reasons).

After the blind was broken in the phase III studies, all patients were given the option to continue on active drug in a open extension of the study. In this open extension, 13 of approximately 300 finasteride-treated patients underwent surgery (5 for urinary retention, 8 for other reasons) presumably within the 12 months after the study was unblinded. Five of these 13 patients had previously been on placebo; the other 8 had been on 1 or 5 mg of finasteride. The majority of the "treatment failures" in the open extension period presumably occurred soon after unblinding. These patients did not likely want to discontinue the blinded portion of the study, but elected to proceed with surgery after the study was unblinded. It would therefore be incorrect to calculate failure rates based on these data.

Five percent of patients dropped out due to lack of efficacy, and an additional 1 percent underwent surgery, for a total failure rate of 6 percent in the first 12 months of treatment. If treatment failure on finasteride occurs at a constant rate over 5 years, the predicted cumulative probability of failure would be 27 percent (90-percent CI 25-29 percent). If, however, the failure rate declines similarly to that seen in other studies (20 percent of initial rate), the projected cumulative failure rate would be 10 percent (90-percent CI 9-12 percent) at 5 years. The rather low "treatment failure" or "retreatment" rate may be partially explained by the fact that about 30 percent of patients in the phase III studies were only mildly symptomatic at entry.

### TUIP

Nine reports are available in the panel's BPH outcome data base to assess the treatment failure rate and the need for retreatment following TUIP (Hellstrom, Lukkarinen, and Kontturi, 1986 ; Dorflinger, Oster, Larsen, et al., 1987 ; Larsen, Dorflinger, Gasser, et al., 1987 ; Nielsen, 1988 ; Delaere, Debruyne, and Moonen, 1983 ; Katz, Greenstein, Ratliff, et al., 1990 ; Mobb, and Moisey, 1988 ; Edwards, Bucknall, Pittam, et al., 1985 ; Orandi, 1990).

Orandi (1990) published the data from his 18-year experience with 753 TUIP procedures in a format that permits an accurate calculation of the incidence density or failure rate over a period from 3 to 60 months. By contrast with other long-term BPH treatment studies, the rate did not decline significantly in years 2 through 5. However, the year-1 failure rate was the highest. If the Orandi data are used to project the 5-year failure rate for all the reported TUIP cases, the cumulative rate was 13 percent (90-percent CI 5-26 percent). If only those studies actually reporting 5-year data are analyzed, the cumulative failure rate is 9 percent (90-percent CI 1-28 percent). Confidence intervals for these two analytical approaches are almost identical.

### TURP and Open Surgery

Treatment data have been reported for 44,832 patients treated by TURP and 17,065 patients treated by open surgery (Roos, and Ramsey, 1987 ; Roos, Wennberg, Malenka, et al., 1989 ; Taylor, and Krakauer, 1991 ; Singh, Tresidder, and Blandy, 1973 ; Ball, and Smith, 1982 ; Aalkjer, 1965 ; Stephenson, Chute, Guess, et al., 1991 ; Meyhoff, and Nordling, 1986).

The study by Roos and Ramsey (1987) reported retreatment data on 1,855 patients following TURP and 844 patients following open prostatectomy. Over an 8-year followup period, 16.8 percent of the TURP patients and 7 percent of the open prostatectomy patients underwent a second prostatectomy. Roos, Wennberg, Malenka, et al. (1989) reported on 8-year retreatment rates for 54,077 patients following TURP and open prostatectomy in Denmark, the Oxford region of England, and Manitoba, Canada. The probability of undergoing a second prostatectomy ranged from 5.0 percent (Denmark, and Oxford region) to 15.5 percent (Manitoba, Canada). For open prostatectomy, the 8-year retreatment probabilities ranged from 1.8 percent (Oxford region) to 4.5 percent (Denmark).

In the data presented by Taylor and Krakauer (1991), the probability of having a repeat prostatectomy after 2 years of followup was 4.7 percent following a TURP and 1.84 percent following an open prostatectomy. Singh, Tresidder, and Blandy (1973) reported retreatment rates on 935 patients following TURP and 217 patients following open prostatectomy. Within 1 year of the initial operation, 2.8 percent in the TURP group required retreatment compared with 0.5 percent in the open prostatectomy group. Stephenson, Chute, Guess, et al. (1991) studied the outcome of surgery in 330 men undergoing prostatectomy for BPH. The probability of reoperation at 5 years was 12.9 percent, the highest reported rate in any of the studies reviewed.

The panel believes there are ample published data overall to reasonably define the retreatment (failure) rates for TURP and open prostatectomy. The cumulative retreatment probability at 5 years for TURP is 10 percent (90-percent CI 9-11 percent) and for open prostatectomy, 2 percent (90-percent CI 1-4 percent). These retreatment rates undoubtedly included reoperation for complications such as bladder neck contracture (see chapter 13).

### Conclusions

Open surgery appears to have the lowest probability of treatment failure and/or need for retreatment within 5 years, when compared with other treatment modalities. The probability for failure requiring retreatment remains constant throughout at least 5 to 8 years of followup for TURP, TUIP, and open prostatectomy. By contrast, balloon dilation and watchful waiting demonstrate a high failure rate the first year and later a decrease in the failure rate throughout the remainder of the followup to 5 years.

Surgical intervention by any technique has a lower retreatment rate than does initial treatment with alpha blockers, finasteride, balloon dilation, or watchful waiting. Probability distributions for these nonsurgical modalities overlap to the extent that there are no statistically significant differences in probabilities of treatment failure. The long-term failure rates for watchful waiting, medical therapy, and balloon dilation remain to be defined in long-term studies. To date, there is no evidence to demonstrate clearly that medical therapy or balloon dilation will lower the future risk of surgery for men being managed by watchful waiting.