# Direct Treatment Outcomes— Late Complications

Surgery may produce scarring in the urethra (stricture) or at the bladder neck (contracture), which may lead to persistent or recurrent urinary symptoms. Urethral stricture and bladder neck contracture often necessitate secondary invasive procedures. The probability for the development of a urethral stricture or a bladder neck contracture, requiring a secondary surgical intervention, ranges from 0.6 to 14.1 percent of patients after open prostatectomy, from 0.65 to 10.1 percent of patients following TURP, and from 2.1 to 4.1 percent of patients following TUIP.

Two late complications that may result from surgical treatment of BPH are clearly defined and reported in many of the series found in the literature. These are urethral stricture and bladder neck contracture (BNC), following either open or transurethral surgery on the prostate (Table 21). The risk of urethral stricture or BNC following balloon dilation has not been reported. The percentage of patients experiencing these complications who required treatment was calculated based on the total number of patients in each series. This may, in some cases, be either an underestimation or an overestimation because of reporting bias. The time interval is highly variable in these studies. However, fibrotic complications are usually evident within 2 to 24 months.

Table 21. Combined analysis for studies of urethral stricture and bladder neck contracture

Treatment modalities | N[1] | Mean[2] | 90% CI[3]
Stricture [4]
Retropubic prostatectomy | 5,271 | 1.0% | 0.2-2.7%
Suprapubic prostatectomy | 3,080 | 5.1% | 0.5-18.4%
Open prostatectomy, any method | 8,634 | 2.6% | 2.8-9.4%
TUIP | 1,218 | 2.65% | 1.85-3.8%
TURP | 12,003 | 3.1% | 0.5-9.7%
Bladder neck contracture [5]
Retropubic prostatectomy | 5,271 | 1.0% | 0.2-3.5%
Suprapubic prostatectomy | 2,204 | 3.0% | 0.3-10.5%
Open prostatectomy, any method | 7,539 | 1.8% | 0.2-6.1%
TUIP | 1,218 | 0.4% | 0.1-1.0%
TURP | 4,152 | 1.7% | 1.3-2.1%
Combined [6]
Retropubic prostatectomy | 5,271 | 1.9% | 0.3-5.7%
Suprapubic prostatectomy | 3,080 | 7.7% | 1.0-24.9%
Open prostatectomy, any method | 8,634 | 4.33% | 0.6-14.1%
TUIP | 1,218 | 2.9% | 2.07-4.1%
TURP | 12,003 | 3.7% | 0.65-10.1%

1. Number of patients in treatment arm.

2. Mean (50%) or point estimate for probability of outcome to occur.

3. Ninety-percent confidence interval (CI) for probability of outcome to occur.

4. Urethral stricture developing as late complication.

5. Bladder neck contracture developing as late complication.

6. Either urethral stricture or bladder neck contracture developing as late complication.

Note: TUIP = transurethral incision of the prostate. TURP = transurethral resection of the prostate.

Treatments for the two conditions include repeated dilation of the urethral stricture or the BNC, surgical treatment such as visual internal urethrotomy of the urethral stricture or the BNC, or open surgical repair of the complication.

## Urethral Stricture After Open Surgery

There are 18 studies reporting the incidence of urethral stricture and/or BNC following open surgical enucleation of the prostate (Attachment D). These studies comprise a total of 8,634 patients. Patients treated by retropubic prostatectomy numbered 5,271, and 3,080 patients were treated by suprapubic prostatectomy. Although men with smaller prostates are thought to be more susceptible to the two complications, no meaningful conclusion can be drawn from these studies regarding correlations between weight of the prostate and incidence of the complications. Only 3 of the 18 studies reported the mean weight, and the mean weight ranges only from 42 to 51 grams in those studies in which it was reported.

Overall, open surgical enucleation resulted in urethral stricture disease in 181 out of 8,634 patients for an incidence of 2.1 percent and a mean of 2.6 percent (Table 21) (90-percent CI 2.8-9.4 percent). The higher risk following suprapubic (mean 5.1 percent), as opposed to retropubic prostatectomy (mean 1.0 percent), cannot be explained. Given the small number of cases reported, it may be artifactual.

## Urethral Stricture After TUIP

Nine studies report the incidence of urethral stricture disease following TUIP (see Attachment D). The risk is 2.65 percent (Table 21) (90-percent CI 1.85-3.8 percent). Of 1,218 patients reported, 21 had the complication. The overall risk of urethral stricture following TUIP does not appear to be markedly lower than that seen following TURP, notwithstanding the shorter operating time of the former.

## Urethral Stricture After TURP

The incidence of urethral stricture disease following TURP is reported in 17 studies with a total of 12,003 patients, with an average age of 67.6 years (Attachment D). Of this total, 269 patients developed urethral stricture disease. The combined analysis indicates the estimated risk to be 3.1 percent (90-percent CI 0.5-9.7 percent). Three studies report an especially high rate of stricture: 16 percent (Nielsen, 1988), 16 percent (Meyhoff, Nordling, and Hald, 1984), and 12 percent (Meyhoff, and Nordling, 1986). Although these studies report a much higher incidence of urethral stricture disease, the complications are carefully documented and the studies are contemporary. In 6 of the 17 studies, the average weight of the removed tissue is reported (mean 21.1 grams, range 7-57 grams). There is no correlation between the weight of tissue resected and the incidence of stricture formation evident in these studies.

Regarding such potential predictors of subsequent strictures as resected weight, the panel reviewed a large body of evidence on the correlation between perioperative parameters and the subsequent probability of scar tissue formation. Individual studies have found positive correlations between urethral stricture or BNC and the resected weight, the operating time, the catheter size and site, the type of instrumentation, and other factors. Unfortunately, the studies conflict with one another. Based on a synthesis of these studies, the panel cannot make any evidence-based recommendations on prevention of the two complications by modifications of operative or perioperative management.

## BNC After Open Surgery

BNC following retropubic prostatectomy is reported for 67 patients out of 5,271, a risk of 1.0 percent (Table 21) (90-percent CI 0.2-3.5 percent). Following suprapubic prostatectomy, 50 out of 2,204 patients developed BNC, a risk of 3.0 percent (90-percent CI 0.3-10.5 percent). These calculated risks reflect the influence of one study, which also influences the calculated risks of urethral stricture. The study (Beck, 1970) reports a 12.84-percent incidence of BNC. Overall, 120 of 7,539 patients following open prostatectomy developed a BNC, a risk of 1.8 percent (90-percent CI 0.2-6.1 percent). Suprapubic prostatectomy appears to have the highest risk of BNC, although this may not be significant.

## BNC After TUIP

Of all the reports describing long-term complications following TUIP, only one study (Orandi, 1985) reports patients developing a BNC (2 of 646 patients). The risk of BNC calculated by combined analysis of these studies is 0.4 percent (90-percent CI 0.1-1.0 percent). This risk is lower than the risk of BNC following TURP by a factor of four.

## BNC After TURP

Only 9 of the 17 studies reporting urethral stricture development following TURP present data on BNC following the same intervention. The incidence ranges from 0 percent to 7.14 percent. Overall, 61 patients of 4,152 had this complication, leading to a calculated risk of 1.7 percent (90-percent CI 1.3-2.1 percent).

No correlation is apparent between the amount of tissue resected and the incidence of BNC, although it had been postulated that BNC is more likely to occur after resection of less than 10 grams of tissue. In one report of 388 patients, the average weight was 57 grams and the incidence of BNC was 0.77 percent (Edwards, Bucknall, Pittam, et al., 1985). In another report of 84 patients, the average resected weight was 23.5 grams and the incidence, 7.14 percent (Bruskewitz, Larsen, Madsen, et al., 1986). In 3 studies totaling 52 patients with average resected weights of less than 20 grams, no patient developed BNC (Hellstrom, Lukkarinen, and Kontturi, 1986 ; Dorflinger, Oster, Larsen, et al., 1987 ; Larsen, Dorflinger, Gasser, et al., 1987).

## Conclusions

Despite differences in reporting and followup interval, several conclusions can be drawn. Fibrotic reaction in the bladder neck and in the urethra can occur following all forms of prostatic surgery. TUIP clearly has the lowest risk of BNC. Despite the common perception that operating time and instrumentation issues influence this risk, the panel could not find clear evidence for this in the literature. In the opinion of the panel, TUIP has a substantially lower risk of scarring in smaller glands than does TURP. However, reoperation rates for persisting manifestations of inadequately treated BPH are higher for TUIP than for TURP or open surgery, and detecting the distinction between scarring and recurrent BPH may be more difficult following TUIP than following TURP or open surgery.