# Direct Treatment Outcomes— Sexual Dysfunction

There is no evidence to suggest that BPH itself, independent of an increasing prevalence of sexual dysfunction related to age, adversely affects sexual function. The most common type of sexual dysfunction seen in men after prostatectomy is retrograde ejaculation. TUIP has a substantially lower incidence of retrograde ejaculation than TURP. Historical data suggest that TURP has a substantial risk of impotence (3.4 to 32.4 percent). However, more recent prospective data demonstrate that impotence attributable to TURP is probably no more common than in BPH patients managed by watchful waiting. Finasteride therapy has a 3- to 4-percent risk of erectile dysfunction, a 3- to 5-percent chance of decreased libido, and a 3-percent risk of impaired ejaculation.

Despite the importance of sexual function in the aging male, in most BPH outcome studies treatment-related sexual dysfunction is crudely assessed -- usually by means of loosely structured physician interviews. Only a few studies evaluate the issue of posttreatment impotence by more scientific methods such as standardized questionnaires, nocturnal penile tumescence studies, penile plethysmography, or other studies. Furthermore, the data available are questionable because frequently the risks are reported without considering whether patients were potent prior to initiation of treatment.

## Prevalence of Impotence

Studies assessing the prevalence of impotence in aging men include the following: Kinsey (1948); Finkle, Moyers, and Tobenkin (1959); Newman and Nichols (1960); Bowers, Cross, and Lloyd (1963); Pearlman and Kobashi (1972).

The age-specific prevalence of impotence as reported in these 5 studies, totaling 7,316 men, is shown in Figure 8. The study by Pearlman and Kobashi (1972) reports not only the frequency of intercourse in men, but the prevalence of impotence in patients with BPH (n = 1,095). The second column in each age bracket in Figure 8 shows the prevalence of impotence in BPH patients as reported by Pearlman and Kobashi. The two columns together show that the increase in the prevalence of impotence in the BPH population parallels the overall increase in the prevalence of impotence in the general population. Based on these five studies, it is evident that the disease process of BPH does not have a major effect on the prevalence of sexual dysfunction.

Figure 8. Prevalence of impotence by age category in the general population and in men with BPH

## BPH Surgery-Related Impotence

The panel identified a number of studies that report in some detail on potency before and after BPH treatment (Dahlen, and Goodwin, 1957 ; Finkle, Moyers, and Tobenkin, 1959 ; Finkle, and Moyers, 1960a, 1960b ;Finkle, and Prian, 1966 ; Freeman, 1961 ; Bowers, Cross, and Lloyd, 1963 ; Gold, and Hotchkiss, 1969 ; Pearlman, and Kobashi, 1972 ; De Nicola and Peruzza, 1974 ; Windle, and Roberts, 1974 ; Finkle, Finkle, and Finkle, 1975 ; Madorsky, Ashamalla, Schussler, et al., 1976 ; Zohar, Meiraz, Maoz, et al., 1976 ; De Baker, Lauwerijns, and Willem, 1977 ; Hargreave, and Stephenson, 1977 ; Hauri, 1982 ; Moller-Nielsen, Lundhus, Moller-Madsen, et al., 1985 ; Bolt, Evans, and Marshall, 1987 ; Libman, and Fichten, 1987 ; Vereecken, 1989 ; Lindner, Golomb, Korzcak, et al., 1991).

Specific data dealing with the study design, the mode of evaluation, the number of subjects, the age of the subjects, the length of followup, the type of surgery performed, and the probability of potency and impotence prior to and after BPH surgery, as well as the incidence of posttreatment retrograde ejaculation, are all reviewed in the BPH Guideline Report.

It is evident from the reported series that even after general surgical procedures not related to the genitourinary tract, 4.3 percent (90 percent CI 0.67-12.8 percent) of patients report postoperative impotence (Table 18). Whether this phenomenon is due to the patient attributing the onset of impotence to a significant event in his life -- in this case, a surgical procedure -- or whether it was actually induced by anesthesia or some other mechanism is unclear. For a more accurate assessment of the "attributable" risk of impotence from prostate surgery, the 4.3 percent mean probability of impotence, reported by the patients following general surgical procedures, can be subtracted from the mean probability of impotence as reported after surgical treatment for BPH and demonstrated in Table 18.

Table 18. Probability of becoming impotent following surgical treatment for BPH

Description | N | Mean Probability | 90% CI
General surgical procedures | 186 | 4.3% | 0.67-12.8%
Perineal prostatectomy | 90 | 32.3% | 17.3-50.4%
Retropubic prostatectomy | 784 | 16.2% | 4.8-35.6%
Suprapubic prostatectomy | 647 | 17.7% | 4.9-39.3%
TUIP | 144 | 11.7% | 4.0-24.4%
TURP | 1,543 | 13.6% | 3.4-32.4%

Note: The percentages indicate the mean (50%) probability and the 90% confidence interval (CI) for the outcome to occur. The number of patients on which the calculation is based is indicated in column "N." Evidence is combined by the hierarchical Bayes' method if not otherwise indicated. TUIP = transurethral incision of the prostate. TURP = transurethral resection of the prostate.

The wide range of uncertainty around the probability of impotence following BPH surgery reflects poor study design, particularly retrospective determination of sexual function. Whether patients had preexisting sexual dysfunction is not addressed in the majority of studies. Clearly, however, perineal prostatectomy has an impotence rate higher than that seen with other types of prostatectomy. The reported risk of impotence following TURP and TUIP (13.6 and 11.7 percent, respectively) is higher in the panel's retrospective meta-analysis than prospective studies suggest.

The panel reviewed preliminary data from a large prospective study by the Veterans Affairs Cooperative Study Group comparing TURP with watchful waiting (Wasson, Reda, Bruskewitz, et al., forthcoming). The data suggest that impotence following TURP is uncommon in men who are functioning normally prior to surgery and that there may be no attributable risk of impotence following TURP.

Further support for a lower estimate of the risk of postoperative impotence comes from the study by Libman, Fichten, Creti, et al. (1989). In this study, the investigators interviewed 72 married men after a transurethral prostatectomy. Socioeconomic status, personal and demographic variables, symptom checklist, psychological status (Brief Symptom Inventory), and marital function (Locke Wallace Marital Adjustment Scale) were assessed. In addition, a variety of tests to evaluate sexual functions was performed. The tests included the Sexual History Form, the Goal for Sex Therapy Scale, the Sexual Self-Efficacy Scale to assess erectile functioning, and the Sexual Interaction Inventory. This study is by far the most detailed determination of sexual functioning following surgery for BPH.

The authors reported that pre- and postsurgery scores correlated highly for all measured parameters except for satisfaction with the current sexual relationship. Men with good presurgical sexual adjustment had a better postsurgery outcome than those with poor adjustment. Younger men were more prone to retain good sexual capabilities and confidence than older men. However, older men with good couple scores were more likely to remain in the well-functioning range on couple behavior and adjustment after surgery. There was an overall decrease in the frequency of intercourse, reduced variability, and decrease in sexual desire, erectile capabilities, and self-confidence. An increase was noted in the prevalence of retrograde ejaculation.

Of greatest importance is that the rating of general couple satisfaction was not adversely affected by the surgery. This study emphasizes that the effects of prostate surgery may differ greatly, depending on whether the focus is on an individual's sexual functioning or on the sexual relationship of a couple -- indicating that these two aspects of sexuality need to be evaluated separately.

## Impotence from Drug Treatment

Review of the literature reveals no evidence that use of alpha blocker drugs is a risk factor for impotence. Finasteride, however, produces sexual dysfunction in a small number of patients.

Of patients taking 5 mg of finasteride per day, 3.3 percent reported decreased libido compared with 1.6 percent on placebo; 2.5 to 3.7 percent reported erectile dysfunction compared with 1.1 percent on placebo. The etiology of this small, but statistically significant effect of finasteride is unclear, since the drug does not lower serum testosterone levels, and since testosterone is presumed to primarily mediate libido and sexual function.

## Retrograde Ejaculation After BPH Treatment

The pathophysiology of retrograde ejaculation is that the bladder neck fails to close during ejaculation, allowing the semen to flow back into the bladder. Other than potential infertility, retrograde ejaculation has no serious medical consequences. Patients may not find retrograde ejaculation troublesome, but it is important that they understand the risk before surgery. In patients not informed preoperatively, more significant sexual dysfunction may occur secondary to the anxiety produced.

Although relatively uncommon, alpha blocker therapy may cause retrograde ejaculation due to relaxation of the bladder neck. This effect is reversible. Among surgical options, as shown in Table 19, TUIP has the lowest probability of producing retrograde ejaculation and should be the operation of choice in men with prostates <30 grams (of resectable tissue as estimated by DRE) who wish to maintain antegrade ejaculation.

Table 19. Probability of retrograde ejaculation following treatment for BPH

Description | Mean probability | 90% CI
Alpha blocker treatment | 6.2% | 3.5-10.9%
TUIP | 24.9% | 6.1-55.1%
TURP | 73.4% | 30.4-96.9%
Open prostatectomy (supra/retropubic) | 77.2% | 46.4-95.2%

Note: The percentages indicate the mean (50%) probability and the 90% confidence interval (CI) for the outcome to occur. Evidence is combined by hierarchical Bayes' formula if not otherwise indicated. TUIP = transurethral incision of the prostate. TURP = transurethral resection of the prostate.

Finasteride does not cause retrograde ejaculation. In clinical trials, however, 2.9 percent of patients on finasteride (5 mg per day) complained of a "decrease or abnormality" in ejaculation. The drug can reduce the ejaculate volume to some degree, and some patients may find this change a problem.