# Direct Treatment Outcomes— Complications

In the treatment balance sheet table, the probability and expected magnitude of symptom improvement must be weighed against possible complications of the intervention, taking into account both the immediate and the long-term risks (see Attachment B). The importance of knowing the risks and harms of therapy, as well as the benefits, is evident in the panel's analysis of patient preferences (see chapter 18). An individual patient may be willing to tolerate his symptoms, or may elect a therapy less effective than surgery, if he views the risks of more effective treatment as too high.

## Complications from Treatment with Drugs

Both finasteride and alpha blocker therapy have adverse effects that can limit tolerability and compliance. Finasteride may cause sexual dysfunction. Alpha blockers may induce tiredness (asthenia), orthostatic hypotension, dizziness, headaches, and other complaints. The panel found no clear evidence for a difference among selective alpha-1 receptor blockers in side effects, recognizing the limitations of a retrospective meta-analytic combination of relatively few studies that were conducted with different thresholds for the reporting of adverse effects. By comparison, the toxicity of the nonselective alpha blocker phenoxybenzamine is high. Based on these findings, the panel recommends only selective alpha-1 receptor blockers for BPH treatment if the alpha blocker option is chosen.

There are two ways to examine the probability of adverse events associated with drug treatment. One is the absolute probability that patients will report an adverse effect. The other is the frequency of the adverse effect over and above that seen in the placebo group. This latter approach is a more accurate reflection of adverse events actually attributable to medication. However, from a patient perspective, it is the overall probability of adverse events associated with a treatment that is usually of most interest.

### Alpha Blocker Treatment

The assessment of the incidence of adverse effects occurring on treatment with alpha receptor blocking agents is complicated by what are likely different thresholds used in reporting adverse effects in individual studies. The BPH outcomes data analyzed include two studies using alfuzosin, two studies using indoramin, one study using nicergoline, five studies using prazosin, five studies using terazosin, and two studies using YM 12617. There are seven studies describing the use of the nonselective alpha blocker phenoxybenzamine. Fifteen studies in the data base are placebo controlled (attachment C).

Data from the studies were analyzed in different ways. Table 14 lists: (1) the total number of patients for whom mild or severe adverse effects were reported; (2) the weighted average for the outcome to occur across studies, based on the number of patients who had the outcome and the total number of patients in each treatment arm; and (3) the mean or point estimate for the probability of the outcome to occur calculated by the confidence profile method.

Table 14. Combined analysis of adverse events during alpha blocker treatment

Treatment modalities | N[1] | Weighted average[2] | Mean[3] | 90% CI [4]
Mild adverse effects [5]
Severe adverse effects [9]
Placebo | 533 | 21.8% | 11.6% | 0.9-40.9%
Phenoxybenzamine (nonselective alpha blocker) | 275 | 31.3% | 49.1% | 14.9-83.9%
Selective alpha-1 blocker[6] | 764 | 18.85% | 13.7% | 2.1-38.7%
Alfuzosin (Bayes)[7] | 271 | 34.7% | 34.7% | 30.1-39.6%
Indoramin (Bayes)[7] | 56 | 8.9% | 9.2% | 4.2-16.7%
Nicergoline (single profile)[8] | 16 | 0.0% | 1.4% | 0.01-11.1%
Prazosin (Bayes)[7] | 102 | 16.7% | 16.7% | 3.2-42.6%
Terazosin (Bayes)[7] | 72 | 29.2% | 29.2% | 21.2-38.7%
YM 12617 | 247 | 2.8% | 3.2% | 1.02-7.2%
Placebo | 580 | 5.0% | 5.0% | 3.7-6.7%
Phenoxybenzamine (nonselective alpha blocker) | 292 | 8.6% | 9.1% | 1.95-23.96%
Selective alpha-1 blocker [6] | 908 | 5.2% | 5.2% | 4.1-6.5%
Alfuzosin (Bayes)[7] | 271 | 9.96% | 9.96% | 7.3-13.4%
Indoramin (Bayes)[7] | 56 | 12.5% | 12.7% | 6.7-21.1%
Nicergoline (single profile)8 | 16 | 0.0% | 1.4% | 0.01-11.15%
Prazosin (Bayes)[7] | 102 | 4.9% | 5.05% | 2.3-9.4%
Terazosin (Bayes)[7] | 178 | 4.5% | 4.6% | 2.5-7.6%
YM 12617 | 285 | 0.0% | 0.08% | 0.0007-0.7%

1. Number of patients available for calculation, all treatment arms.

2. Weighted average of outcome based on number of patients with outcome and total number of patients in arm.

3. Mean (50%) or point estimate for probability of outcome to occur.

4. Ninety-percent confidence interval (CI) for probability of outcome to occur.

5. Not leading to discontinuation of treatment.

6. All selective alpha-1 receptor blocker studies combined.

7. Combined by Bayes' formula (if not specified, by hierarchical Bayes' formula).

8. Only one study available for analysis.

9. Leading to discontinuation of treatment.

Due to inconsistencies in reporting and lack of homogeneity in the available outcomes data, there is a considerable difference between the raw and the weighted average for most of the treatment arms under consideration. This assertion holds true for both the mild and severe adverse effects. These factors further support the use of Bayesian methods for combining evidence in which the uncertainty, evident in the wide range of reported incidences of side effects, becomes manifest in a wide CI around the point estimates of these outcomes.

The mean probability of mild adverse effects for all selective alpha-1 blocker studies is 13.7 percent (90-percent CI 2.1-38.7 percent). This estimate is only slightly higher than the mean probability for all placebo arms of 11.6 percent (90-percent CI 0.9-40.9 percent). The probability for mild adverse effects with phenoxybenzamine treatment is significantly higher, with a mean probability of 49.1 percent (90 percent CI 14.9-83.9 percent). The most common mild adverse side effects are mild asthenia (tiredness or weakness), headaches, nasal congestion, and mild dizziness.

The mean probability of severe adverse effects leading to discontinuation of the study ranges from 0.08 percent (YM 12617) to 12.7 percent (indoramin) for selective alpha-1 blockers, with an overall combined mean probability of 5.2 percent (90-percent CI 4.1-6.5 percent). The most common severe adverse effects are orthostatic hypotension, dizziness, and significant asthenia.

Recently published safety data for terazosin are similar to those seen in the combined analysis (Lepor, Auerbach, Puras-Baez, et al., 1992).

This estimate is only marginally higher than the mean probability of 5.0 percent (90-percent CI 3.7-6.7 percent) observed for the 580 patients treated in placebo arms. The mean probability for discontinuation because of severe adverse effects was almost twice as high for the 292 patients treated with phenoxybenzamine (9.1 percent; 90-percent CI 1.95-23.96 percent) than for the selective alpha-1 blockers.

### Finasteride

Finasteride was approved by the FDA for treatment of BPH on June 19, 1992. The clinical data discussed in this section are based on five studies conducted by the manufacturer of finasteride (Merck, Sharp & Dohme Research Laboratories, 1992).

About 5 percent (82 of 1,645) of all patients dropped out of the 12-month phase III studies due to lack of therapeutic response or worsening of symptoms. Of patients treated with 5 mg of finasteride per day, 5.2 percent (28 of 543) discontinued the study because of adverse events, primarily sexual adverse events, prostate cancer, and urinary retention. This rate is similar to the 5.0 percent dropout rate in the placebo-treated patients.

Seventeen percent of patients (92 of 543) had an adverse event that may have been drug related according to the investigators. However, only the occurrences of ejaculatory disorders (2.9 percent) and erectile impotence (3.7 percent) were significantly more common in the finasteride-treated patients than in the placebo-treated patients. No deaths were attributable to the use of finasteride, and there is no measurable risk of urinary incontinence or risk of operative complications with its use.

For a discussion of adverse events either tolerated during treatment or leading to discontinuation of the study, only the phase III data are utilized. Table 15 lists adverse events considered possibly, probably, or definitely drug related by the investigators and occurring in >= 0.5 percent of patients in these studies. The table shows percentages for placebo-treated patients and for patients treated with 1 mg of finasteride and with 5 mg (the ultimately approved dose).

Table 15. Percentages of adverse events in >=0.5% of patients (phase III finasteride studies only)

Adverse Event | 1 mg finasteride (n = 547) | 5 mg finasteride (n = 543) | Placebo (n = 555)
Abdominal pain | 0.9 | 0.9 | 0.4
Asthenia | 0.9 | 0.9 | 0.7
Diarrhea | 0.7 | 0.0 | 0.0
Nausea | 0.2 | 0.4 | 0.7
Flatulence | 0.0 | 0.6 | 0.5
Headache | 0.5 | 0.9 | 0.5
Decreased libido | 4.9[1] | 3.3 | 1.6
Dizziness | 0.7 | 0.6 | 0.7
Skin rash | 0.7 | 0.6 | 0.2
Ejaculation disorders | 2.7[2] | 2.9[3] | 1.1
Erectile impotence | 4.0[1] | 3.7[1] | 1.1
Orgasm dysfunction | 0.2 | 0.6 | 0.2
Testicular pain | 0.4 | 0.6 | 0.4

1. p < 0.01 compared with placebo.

2. p < 0.05 compared with placebo.

3. Decreased ejaculatory volume in 15 of 16 patients.

Concerns have been raised about whether long-term adverse effects might be seen as a result of increases in circulating testosterone (averaging about 10 percent) among finasteride-treated men. These changes in serum testosterone are small and remain within the normal range. Their clinical significance is questionable. Intraprostatic levels of testosterone increase more significantly, but the biologic significance of this finding is uncertain.

The reduction in serum PSA values seen with finasteride treatment as a result of its mode of action have raised concern about whether the early detection of prostate cancer might be impaired among finasteride-treated men. Finasteride decreases serum PSA levels by approximately 50 percent in men with BPH and is known to partially suppress serum PSA in men with prostate cancer (see chapter 3). Yet it is not known whether finasteride treatment actually reduces the information value of PSA among men with BPH or the detection rate for prostate cancer. Furthermore, the benefits of early detection of prostate cancer remain undefined.

## Surgical Morbidity

For the probability that an immediate complication will occur following open prostatectomy, TURP, or TUIP, there is statistically no significant difference among these treatment modalities, except for unique fluid and electrolyte problems seen with TURP.

Surgical morbidity comprises complications occurring within the immediate postoperative period. Balloon dilation is included in this discussion of surgical complications because, although not truly a surgical procedure, it is invasive and its complications, while uncommon, resemble those associated with surgery. Immediate surgical complications (morbidities) include, but are not limited to, dilutional hyponatremia ("TURP syndrome"), perioperative infection, fever, urinary retention, hemorrhage requiring transfusion, myocardial infarction, stroke, and incisional complications.

### Open Prostatectomy

As shown in Table 16, the mean probability for immediate complications following open prostatectomy by any method was calculated at 21 percent (90-percent CI 7.0-42.7 percent). For retropubic open prostatectomy, the mean probability was calculated at 18.7 percent (90-percent CI 5.7-39.8 percent), and for suprapubic open prostatectomy at 25.2 percent (90 percent CI 9.5-47.5 percent). Although the probability for surgical complications appears higher for suprapubic prostatectomy, the difference is not statistically significant.

Types of complications reported by the investigators vary from study to study, limiting the value of the data. The reports originate from as early as 1954 to as late as 1987. No substantial reports on complications following open prostatectomy have been published since 1987, which reflects the shift in surgery toward TURP. Because of variations in data reporting, it was not possible to compare the incidence of individual complications. Rather, all complications were combined that were Table 16. Analysis of immediate surgical complications considered significant to the physician and patient, regardless of the particular type of complication.

Table 16. Analysis of immediate surgical complications

Treatment modalities | Surgical complications[1]
Treatment modalities | N2 | Weighted average [3] | Mean [4] | 90% CI [5]
| Bleeding intervention [6]
| N2 | Weighted average [3] | N [2] | Weighted average [3]
Balloon dilation | 323 | 2.8% | 4.8% | 1.8-9.9%
Open prostatectomy, any method | 9,538 | 24.5% | 21.0% | 7.0-42.7%
TUIP | 1,243 | 17.4% | 12.1% | 2.15-33.3%
TURP | 11,693 | 11.9% | 14.95% | 5.2-30.7%
Balloon dilation | 256 | 1.95% | 323 | 0.0%
Open prostatectomy, any method | 7,761 | 1.5% | 6,989 | 35.06%
TUIP | 1,226 | 0.5% | 1,243 | 1.2%
TURP | 7,184 | 2.2% | 7,603 | 12.5%

1. Any surgical complications listed in report regardless of severity.

2. Number of patients available for calculation.

3. Weighted average of outcome based on number of patients with outcome and total number of patients in arm.

4. Mean (50%) or point estimate for probability of outcome to occur.

5. Ninety-percent confidence interval (CI) for probability of outcome to occur.

6. Incidence of patients requiring intervention for perioperative

7. Incidence of patients receiving blood transfusion perioperatively (great variation in threshold for transfusion depending on publication date and country of origin).

Note: TUIP = transurethral incision of the prostate. TURP = transurethral resection of the prostate.

### Endoscopic Surgery

Investigators have reported that immediate surgical complications occur in 12.1 percent (90-percent CI 2.15-33.3 percent) of TUIP cases.

Because of the wide CIs, there are no statistically significant differences in the probability for complications to occur following treatment with open prostatectomy, TURP, or TUIP. It should be noted that differences in types of complications occurring after any of the individual treatments are considerable; the extent to which this reflects true differences in complications rather than differences in reporting is unclear. Also, perceptions of what constitutes "significant" complications for reporting purposes may differ between investigators and patients.

The data are further confounded by the fact that reports describing the outcomes of open prostatectomy are generally 10 to 15 years older than those describing either TURP or TUIP, and reports describing balloon dilation of the prostatic urethra are all less than 5 years old. Improved surgical technique, improved anesthesia technique and monitoring, and supportive medical care must be taken into account when complications are compared.

### Blood Transfusions

As reported in the literature, the probabilities for patients receiving blood transfusions in the immediate perioperative period vary widely. In some studies, the number of patients receiving transfusions seems excessive by current standards. One explanation is the time period of the data reported. Prior to the onset of the acquired immunodeficiency syndrome (AIDS) epidemic, blood transfusions were used more liberally in surgery.

Ranking the open surgical and TURP series by year of publication reveals that those studies published prior to 1980 reported a significantly higher utilization of blood transfusions than those published after 1980. Although not evident in the literature review, it is unlikely that transfusion rates for TURP now exceed 5 to 10 percent. Transfusions have not been reported following balloon dilation.

### TURP Syndrome

TURP syndrome, which occurs in approximately 2 percent of patients undergoing TURP (Mebust, Holtgrewe, Cockett, et al., 1989), is characterized by mental confusion, nausea, vomiting, hypertension, bradycardia, and visual disturbances. The syndrome is clearly related to the absorption of the hypotonic fluid used for irrigation during the procedure, with subsequent dilutional hyponatremia (Harrison, Boren, and Robison, 1956). The risk of TURP syndrome is higher if the gland weighs more than 45 grams and resection (operative) time exceeds 90 minutes (Mebust, Holtgrewe, Cockett, et al., 1989). The condition can be treated by diuresis or the infusion of hypertonic saline.

### Epididymitis and Urinary Tract Infection

Two infectious complications of surgical procedures for BPH have been reported separately in many studies. They are posttreatment epididymitis and urinary tract infection. With the exception of balloon dilation, which has a lower risk of both complications, the other modalities do not differ significantly in the estimated risk of either epididymitis or urinary tract infection (Table 17). Vasectomy does not decrease the risk of postoperative epididymitis.

Table 17. Combined analysis of rates of epididymitis and urinary tract infection during followup

Treatment modalities | Epididymitis
Treatment modalities | N[1] | Median[2] | 90% CI[3]
| Urinary tract infection
Balloon dilation | 127 | 0.7% | 0.02-4.15%
Retropubic prostatectomy | 3,583 | 2.45% | 0.8-5.5%
Suprapubic prostatectomy | 3,129 | 3.6% | 0.4-12.6%
Open prostatectomy, any method | 6,963 | 2.6% | 0.4-8.2%
TUIP | 958 | 3.04% | 0.09-16.3%
TURP | 12,677 | 1.0% | 0.09-4.5%
Balloon dilation | 291 | 4.2% | 0.25-18.2%
Retropubic prostatectomy | 688 | 2.6% | 0.1-12.9%
Suprapubic prostatectomy | 1,595 | 12.5% | 5.0-24.3%
Open prostatectomy, any method | 2,566 | 13.4% | 2.13-31.6%
TUIP | 477 | 12.45% | 1.6-38.25%
TURP | 9,946 | 15.5% | 3.4-38.3%

1. Number of patients available for calculation.

2. Median (50%) probability for outcome to occur.

3. Ninety-percent confidence interval (CI) for probability of outcome to occur.

Note: TUIP = transurethral incision of the prostate. TURP = transurethral resection of the prostate.