# Overview

## Purpose and Scope

On December 19, 1989, the Omnibus Budget Reconciliation Act (Public Law 101-239) added a new title IX to the Public Health Service Act establishing the Agency for Health Care Policy and Research (AHCPR). AHCPR was created to enhance the quality, appropriateness, and effectiveness of health care services and access to such services. Section 911 of the Act establishes within AHCPR the Office of the Forum for Quality and Effectiveness in Health Care. Section 912 directs the Forum to facilitate the development and periodic review and updating of:

Clinically relevant guidelines that may be used by physicians, educators, and health care practitioners to assist in determining how diseases, disorders, and other health care conditions can most effectively and appropriately be prevented, diagnosed, treated, and managed clinically.

The central purpose of this Clinical Practice Guideline is to define the most effective methods for diagnosing benign prostatic hyperplasia (BPH) and to identify and describe the most appropriate treatments for BPH based on patient preference and clinical need.

Recommendations in this Clinical Practice Guideline are intended for clinicians who examine, treat, and care for men with BPH. They include urologists, family physicians, internists, geriatricians, and nurses in medical-surgical, acute care, geriatric, home, and other settings. The recommendations are also intended to be useful to patients and family members, health care administrators, policy analysts, and others.

## Background

BPH is a noncancerous enlargement of the prostate gland. The prostate begins to grow during middle age in the majority of men and even earlier in some. Data from 5 major autopsy studies (Berry, Coffey, Walsh, et al., 1984), involving 1,075 prostate glands, demonstrate that the initial development of BPH can begin at 25 to 30 years of age, with a prevalence of 10 percent in that age range. With increasing age, the prevalence of histologically identifiable BPH increases so that by age 60, it is greater than 50 percent. By age 85, the prevalence of BPH is xx percent.

Histologically, the enlargement is a true hyperplastic process, involving an increase in the number of both epithelial and smooth muscle cells, as well as an increase in connective tissue (McConnell, 1990). The human prostate is surrounded by a dense fibrous capsule. Growth of the prostate produces an inward transmission of pressure on the urethra, leading to increased resistance to urine flow.

The disease process leading to development of symptoms commonly referred to as prostatism has three components: histologic prostatic hyperplasia, an increase in outflow resistance, and the response of the bladder (detrusor) muscle to obstruction. Much about the process is not well understood. For example, the correlation between prostate size, degree of outlet obstruction, and severity of urinary symptoms is weak. The prostate may enlarge without producing urodynamic obstruction or symptoms. Patients may be physiologically obstructed with minimal enlargement. At the same time, there are patients who have histologic hyperplasia and urodynamic evidence of obstruction without bothersome symptoms, a condition called "silent" prostatism. Most important, the symptoms of BPH are not specific. Other causes of bladder outlet obstruction (for example, urethral stricture) and primary diseases of the bladder can produce identical symptoms.

The dominant risk factors for the development of BPH are increasing age and the presence of androgens. Epidemiologic and basic scientific knowledge are still insufficient for understanding the etiology of the disease. Long-term outcome data regarding the natural history and the treatment of BPH are lacking, and indicators to aid in the proper timing of treatment for BPH are sparse. In large part because of these uncertainties, there is significant geographic variation in BPH treatment patterns.

### Complications of BPH

Little is known about the ultimate complications and morbidity associated with untreated BPH. Internationally, between 20 and 50 percent of patients are in urinary retention when they undergo prostate surgery. However, the likelihood that a patient with a given symptom complex will go into complete urinary retention over a given timespan is not well defined.

Even less is known about the cumulative risk of obstructive uropathy and chronic renal failure among men with BPH. Patients with histologic hyperplasia and urodynamic obstruction but without bothersome symptoms are said to have "silent" BPH. Although this condition is probably rare, it does occur (Mukamel, Nissenkorn, Boner, et al., 1979 ; Powell, Smith, and Feneley, 1980 ; George, Feneley, and Roberts, 1986 ; Nissenkorn, Savion, and Servadio, 1988 ; Parys, Machin, Woolfenden, et al., 1988 ; Sacks, Aparicio, Bevan, et al., 1989 ; Sarmina, and Resnick, 1989 ; Ghose, 1990). It is difficult to identify a clinical indicator that might be useful in predicting which patients will develop serious BPH complications without bothersome symptoms. Only large-scale screening efforts could identify those few patients with silent prostatism.

A small fraction of patients have urinary tract infections when they are treated for BPH, but it is unknown what risk factors predispose men to this complication. Also unknown is the extent to which a urinary tract infection in men with BPH predisposes them to renal function deterioration.

Bladder decompensation as a result of chronic outlet obstruction may be a long-term complication of untreated BPH in some patients. However, the probability of detrusor muscle decompensation, particularly decompensation not reversible by surgery, in men who are following a strategy of watchful waiting is unknown.

Bladder stones may occur as a result of bladder outlet obstruction, urinary tract infection, a retained foreign body (such as a fragment of a catheter balloon), and dietary factors. The prevalence of bladder stones in men who undergo surgery for BPH is approximately 1 to 2 percent. The incidence of bladder stones over time in men with symptomatic BPH is unknown.

### Mortality

Accurate data on BPH as a primary cause of death are currently not available for most countries in the world. Mortality ascribed to BPH varies from region to region and from country to country. Ekman (1989) has attempted to use World Health Organization death rates for BPH from 50 countries, presenting the death rates as the number of deaths per 100,000 males age 45 and older. The reported death rates ranged from 29.7 per 100,000 men over 45 years in Eastern Germany (1984) to 0.5 per 100,000 males older than 45 years in Singapore (1985). The reported rate for the United States is 1.8 per 100,000 (1983). However, lack of uniformity in criteria for attributing deaths to BPH limits the usefulness of these data.

### Quality of Life

Although mortality from BPH is extremely rare in the United States and serious complications are uncommon, the symptoms of prostatism are bothersome to many patients. If symptoms interrupt normal daytime activities or sleep, create anxiety, or reduce perception of general health, the quality of life can decline significantly. Yet, the degree of "bothersomeness" may be dramatically different for different patients with the same degree of symptom severity (Barry, Fowler, O'Leary, et al., 1992a). Because BPH is primarily a quality-of-life disease, and because significant variations do exist in individual patients' perceptions of bothersomeness and treatment risk, the BPH Guideline Panel concluded that the patient should play a central role in determining the need for treatment. A caring health care provider and patient can work together to reach an optimal treatment decision.

### Practice Variation

Rates of prostatectomies performed per population unit vary greatly among different countries due to differences in health care delivery systems. Rates of prostatectomies performed also vary greatly between small geographic areas, including areas within the United States (McPherson, Wennberg, Hovind, et al., 1982 ; Wennberg, Mulley, Hanley, et al., 1988). The rate of prostatectomies may vary as much as fourfold between small geographic areas (Barry, 1991). These variations are unlikely to be due to geographic differences in disease prevalence or severity and may often be the result of variations in decisionmaking by individual practitioners.

The variation in physician decisionmaking is significant regarding indications for BPH treatment. As noted above, this variation exists in part due to the uncertainty in the medical literature regarding the natural history of BPH and its treatment outcomes. Also, current BPH practice policies, developed by individual State peer review organizations (PROs) to assess the "appropriateness" of surgery for reimbursement purposes, are highly variable between States.

Overall, the number of procedures being performed is high. It is estimated that one in every four men in the United States will undergo treatment for the relief of symptomatic BPH by the age of 80 (Barry, 1990, 1991). In 1990, approximately 335,000 surgical procedures for BPH -- most commonly transurethral resection of the prostate (TURP) -- were performed in the United States. TURP is the second most common surgical procedure performed in Medicare-age men, surpassed only by cataract surgery. The resulting total cost is an estimated $2 billion to $3 billion per year (Holtgrewe, Mebust, Dowd, et al., 1989).

A survey of American urologists revealed that TURP represents 38 percent of the major surgical procedures they performed and 24 percent of their total work load (Holtgrewe, Mebust, Dowd, et al., 1989). The surgical fee for transurethral prostatectomy in this survey ranged from $998 in the southern United States to $1,829 in the Northeast. The number of TURPs performed by each urologist dropped from 101 in 1962 (number of respondents = 266) to 67 in 1986 (number of respondents = 219).

Demographic trends may affect these numbers. The population of American males over 65 years of age will increase significantly by the year 2000. The impact of an aging population on the cost of BPH treatment is obvious. The rate of prostatectomies increases dramatically with increasing age (Glynn, Campion, Bouchard, et al., 1985 ; Arrighi, Guess, Metter, et al., 1990).

Although surgical costs are significant, the growing number of nonsurgical therapies for BPH may indirectly increase costs further because of additional retreatment costs. Some men will choose nonsurgical therapies instead of surgery initially, but some will still eventually undergo TURP. Moreover, the availability of treatments with fewer side effects may draw many more men into the medical system for treatment. This trend has been bolstered by advertising campaigns designed to swell the numbers of men seeking treatment. An investment group (Shearson, Lehman, and Hutton) predicts that the percentage of the eligible population being treated for BPH might increase from 15 to 70 percent between the years 1990 and 1995, expanding the total number of patients treated per year from 450,000 to 2.1 million (McCarthy, and Willard, 1990). However, it is suggested by the same group that the percentage of patients treated surgically will drop to 40 percent, while the percentage of patients treated with presumably less expensive drugs and other devices will increase accordingly. This projection may not be accurate, but it clearly demonstrates that industrial interests will seek to influence the decisions of patients and health care providers.

The high prevalence of BPH in the Medicare population, the unexplained geographic variations in practice patterns, and the high cost of treatment all make BPH an appropriate candidate for an evidence-based guideline.

In developing guideline recommendations for the diagnosis and treatment of BPH, the panel members were themselves guided throughout their deliberations by the idea that the best interest of the patient should be the highest goal of any health care provider. The basic motto "Primum Non Nocere" ("Above all else, do no harm") is especially relevant for evaluation and treatment of a disease that is very rarely lethal and has widely varying effects on the quality of life of the men afflicted by it.

## Methodology for Guideline Development

The BPH Guideline Panel developed recommendations on the basis of (1) a structured assessment of the clinical benefits and harms of diagnostic techniques and treatment interventions and (2) an analysis of patient preferences. The assessment of clinical benefits and harms was intended to determine which practices produce the best health outcomes for patients in the aggregate sense. The analysis of patient preferences was intended to address differences in patient choices related to treatment.

Panel members were appointed by AHCPR after it requested input from professional and health care consumer organizations and individuals. Academic and private-practice urologists, internists, a family practice physician, a radiologist, and a urological nurse provided expertise in surgical and/or nonsurgical therapy, epidemiology and natural history, patient care practices, health outcomes research, urodynamics, and cancer detection. A variety of consultants advised the panel on statistical analysis, guideline development, and cost analysis. Patients with BPH gave their input to the panel through a formal patient preference analysis (discussed in chapter 18). Written and verbal testimony from a variety of patient, medical, and industrial groups and individuals was also requested and obtained. The panel endeavored to meet the following goals:

1. Review all the available published literature on BPH diagnosis and treatment.
2. Explicitly describe the outcomes of each treatment option, as well as the performance of BPH diagnostic tests.
3. Determine the net value of BPH treatments and diagnostic tests
4. Assess the treatment preferences of individual patients with varying symptoms of BPH.
5. Develop clinically relevant guideline recommendations to assist patients and physicians in a shared decisionmaking process.

### Literature Review

The BPH Guideline Panel conducted an extensive literature review on BPH, utilizing the Cumulated Index Medicus and MEDLINE data bases. The comprehensive retrieval of published manuscripts and relevant unpublished material yielded approximately 1,200 abstracts for review. More than 200 manuscripts were chosen for indepth analysis. The panel used only articles published in peer-reviewed, mostly English-language, journals. Excluded as a rule were articles in non-peer-reviewed journals, book chapters, advertisements, and technical and promotional information from device manufacturers or pharmaceutical makers. Any exception was documented with a rationale for the exception. In addition, the panel sought available evidence on the costs of BPH and its treatment. Published reports and expert opinions helped provide insight into the problem.

### Analysis Methodology

The BPH Guideline Panel adapted an explicit approach to designing practice policies as outlined by David M. Eddy, MD, PhD (1992). In this approach, the specific data, subjective judgments, patient preferences, and techniques utilized in generation of the policy are explicitly articulated.

The major limitation of an explicit approach to a BPH practice policy is the paucity of well-designed clinical research studies available in the literature. The small number of randomized clinical trials of treatments and the lack of information concerning the sensitivity, specificity, and predictive value of diagnostic tests significantly limit the quality and strength of the guidelines generated. However, the use of an explicit approach also led to the development of a clinical research agenda to address this problem.

Syntheses of the results from the structured literature reviews utilized the confidence profile method developed by Eddy and Hasselblad (Eddy, 1989 ; Eddy, Hasselblad, and Shachter, 1990 ; Eddy, and Hasselblad, 1992). Analyses of combined data from a variety of treatment studies were performed using the confidence profile method software package FAST*PRO, which allows the calculation of confidence profiles (or confidence intervals [CIs]) around the mean or median probability for a given outcome to occur (Eddy, and Hasselblad, 1992).

The confidence profile method is based on Bayesian statistical theory. The combination of evidence is performed using either Bayes' formula or the hierarchical Bayes' formula (Adar, Critchfield, and Eddy, 1989 ; Eddy, 1989 ; Eddy, Hasselblad, and Shachter, 1990). Unless otherwise indicated, the hierarchical Bayes' formula was used for all outcome analyses presented in this Clinical Practice Guideline.

The panel elected to report the results of the mathematical combination of evidence as a 90-percent CI (5th to 95th percentile) to indicate numerically the range of uncertainty about the probability of a given outcome. For example, if the 90-percent CI for the combined evidence for a particular treatment outcome ranges from 69 to 74 percent (90-percent CI 69-74 percent), it is known that for every 1,000 such confidence intervals constructed, about 900 of them will contain the true value of this outcome.

Every outcome the panel thought important to patients receiving treatment for BPH was analyzed using the confidence profile method software FAST*PRO. Evidence from all studies reporting the outcome was combined for each treatment modality. The data obtained from the analyses were used for the patient preference survey, as these data currently represent the panel's best estimates of the relevant outcome probabilities.

### Guideline Terms

An important factor in the use of clinical practice guidelines is their degree of flexibility (Eddy, 1990a, 1992). Terms utilized in this Clinical Practice Guideline to denote degree of flexibility in the clinical decisionmaking process are described below.

In reference to diagnostic tests, the panel utilized the terms recommended, optional, and not recommended to indicate desirability of specific diagnostic interventions. If a test was categorized as optional, there is clear evidence of its benefit for certain patients. However, the data are insufficient to demonstrate the test's value for routine patients in confirming the diagnosis of BPH and predicting the results of treatment, and the definition of normal and abnormal test values may be uncertain. The evidence is thus insufficient to mandate use of the test prior to a decision to treat.

If a test was not recommended, the panel believed there is sufficient evidence to indicate that the test does not have value or has potential harms that exceed its potential benefits in routine cases.

With regard to treatment policies, the panel utilized the terms standard, guideline, and option to denote intended degree of flexibility. The meaning of each term is explained below.

A treatment policy is considered a standard if the health and economic consequences of the intervention are sufficiently well-known to permit a conclusion that the intervention is clearly superior to all alternatives. In addition, a standard requires virtual unanimity among patients about the desirability or undesirability of the intervention and knowledge of the potential outcomes of both the treatment and the alternatives. Virtual unanimity implies that at least 95 percent of the people asked agree on overall desirability of the treatment, relative to the alternatives.

A treatment policy is considered a guideline if the outcomes of the intervention are well-enough understood to permit a conclusion that the treatment is probably superior (or inferior) to all alternatives and is preferred (or not preferred) by an appreciable, but not unanimous majority of patients (60 to 95 percent of people agreeing on overall desirability, and proper use). Depending on the patient, the setting, and other factors, guidelines can and should be tailored to fit individual needs.

A treatment policy is called an option if (1) the outcomes are not known with certainty, (2) the outcomes are known but patient preferences are not, or (3) patient preferences are evenly divided (40 to 60 percent of people preferring the intervention, with the remainder preferring an alternative). Even division can represent indifference on the part of patients or a wide but even division of preferences. For different reasons, all options are intended to be flexible. Any policy could therefore be an option with outcome uncertainty, an option with preference uncertainty, an option with indifference in regard to preferences, or an option with division of preferences.