# Contributors [1]

Consultants
- Hanan Bell, PhD
- Clinical Policies Analyst
- American Academy of Family Physicians
- Victor Hasselblad, PhD
- Duke University
- Peter Rowley, MD
- Professor of Medicine, Pediatrics, Genetics, Microbiology, and Oncology
- University of Rochester
- Robert H. Sprinkle, MD, PhD
- Center for Health Policy Research and Education
- Duke University
- Martin Steinberg, MD
- Professor of Medicine
- Associate Chief of Staff for Research
- VA Medical Center,
- Jackson, MS

Panel Staff
- Hanan Bell, PhD
- Methodologist
- American Academy of Family Physicians
- Patience Ejiogu-Akinosho, MPA, MPH
- Research Coordinator
- Columbia University

Sickle Cell Disease Guideline Peer Reviewers
- Alfred O. Berg, MD, MPH
- Professor and Associate Chair
- Department of Family Medicine
- University of Washington School of Medicine
- Seattle, WA
- George Buchanan, MD
- Professor of Pediatrics
- University of Texas
- Health Science Center
- Dallas, TX
- George Cunningham, MD, MPH
- Chief, Genetic Disease Branch
- Department of Health Services
- State of California
- Berkeley, CA
- James R. Eckman, MD
- Associate Professor of Medicine
- Emory University School of Medicine
- Atlanta, GA
- Ronald W. Hinkson
- Health Educator
- Sickle Cell Council of New Mexico, Inc.
- Albuquerque, NM
- George C. Hoffman,
- MB, B Chir, FRC Path
- Laboratory Hematology
- The Cleveland Clinic Foundation
- Cleveland, OH
- Dolores E. Jackson,
- MPA, RN, CNAA
- Associate Executive Director, Nursing Services
- Woodhull Medical and Mental Health Center
- Brooklyn, NY
- J. Mehsen Joseph, PhD
- Director, Laboratories Administration
- Maryland Department of Health and Mental Hygiene
- Baltimore, MD
- Archie B. Lewis, MSW
- Coordinator,
- Ohio Sickle Cell Program
- Ohio Department of Health
- Columbus, OH
- Patricia Lowery, MD
- Children's Health Center
- Franktown, VA
- Astrid Mack, PhD
- Comprehensive Sickle Cell Program
- University of Miami
- School of Medicine
- Miami, FL
- Virginia V. Michels, MD
- Chairman,
- Department of
- Medical Genetics
- The Mayo Clinic
- Rochester, MN
- Kwaku Ohene-Frempong, MD
- Associate Professor of Pediatrics
- University of Pennsylvania
- Philadelphia, PA
- Susan R. Panney, MD
- Director,
- Office of Hereditary Disorders, LFHA
- Maryland Department of Health and Mental Hygiene
- Baltimore, MD
- Kenneth A. Pass, PhD
- Director, Newborn Screening Program
- New York State Department of Health
- Albany, NY
- Howard Pearson, MD
- Professor of Pediatrics
- Yale University School of Medicine
- New Haven, CT
- Darleen R. Powars, MD
- Professor of Pediatrics, Hematology/Oncology
- University of Southern California
- Los Angeles, CA
- Gladys Robinson
- Executive Director
- Triad Sickle Cell Anemia Foundation
- Greensboro, NC
- Robert M. Schmidt, MD, MPH, PhD
- Professor of Hematology,
- Clinical Science and Gerontology
- San Francisco State University
- San Francisco, CA
- Margaretta Seashore, MD
- Department of Genetics
- Yale School of Medicine
- New Haven, CT
- John E. Sorrentino
- Executive Director
- New England Regional Newborn Screening Program
- Jamaica Plain, MA
- Brad L. Therrell, PhD
- Director,
- Clinical Services Division
- Bureau of Laboratories
- Texas Department of Health
- Austin, TX

Pilot Reviewers
- Howard Anderson
- President,
- Midwest Association for Sickle Cell Anemia
- Chicago, IL
- Woodrow Brown
- Executive Director,
- Louvenia D. Barksdale Sickle Cell Anemia Foundation
- Spartanburg, SC
- John Chenault
- Executive Director,
- Sickle Cell Awareness Group of Greater Cincinnati
- Cincinnati, OH
- Barbara Davis Clark
- President,
- Sickle Cell Association of Connecticut
- Hartford, CT
- Julia Davis
- President,
- Volunteers in Aid of Sickle Cell Anemia
- Philadelphia, PA
- Magda B. Finch, MSN
- Genetic Screening Coordinator,
- Virgin Islands Department of Health
- Kings Hill, St. Croix, VI
- Vince Ford
- Executive Director,
- James R. Clarke Memorial Sickle Cell Foundation
- Columbia, SC
- Judith R. Harris
- Executive Director,
- Sickle Cell Council of New Mexico
- Albuquerque, NM
- Ella Holmes
- President,
- Harrison County Sickle Cell Foundation
- Gulfport, MS
- Lenora E. Nash
- Executive Director,
- Sickle Cell Organization of the Inland Counties
- Riverside, CA
- Marble Rice
- Executive Director,
- Oklahoma Chapter NASCD
- Tulsa, OK
- Gladys Robinson
- Executive Director,
- Triad Sickle Cell Anemia Foundation
- Greensboro, NC
- Fontanette White
- Executive Director,
- Sickle Cell Anemia Association of Texas
- Ft. Worth, TX
- Pat Williams
- District Coordinator,
- Baton Rouge Sickle Cell Anemia Foundation
- Baton Rouge, LA
- Marcia Wright
- Executive Director,
- Eastern Area Sickle Cell Association
- Jacksonville, NC