# Biosketches: Sickle Cell Disease Guideline Panel Members

- Beverly Ames
- Consumer Representative

Mrs. Ames is the parent of a child with sickle cell disease. She has been an advocate for her child at school and in the community, seeking resources which would allow the child to reach his full potential as an individual and enjoy the pleasures of childhood, including summer camp. She was recently a participant in a multidisciplinary conference at Children's Hospital, Washington, DC, on support for children with sickle cell disease.

- Kwame Anyane-Yeboa, MD
- Associate Professor of Pediatrics
- Columbia University

Dr. Anyane-Yeboa is an Associate Professor of Clinical Pediatrics and Genetics at Columbia University and is Director of the Division of Clinical Genetics at the Presbyterian Hospital, New York City. He also has served as President of the New York State Genetics Task Force and is a member of the New York State Sickle Cell Implementation and Advisory Committees. He serves as a consultant in genetics to the Winthrop University Hospital, Harlem Hospital Center, and St Mary's Hospital for Children. He has published articles on the manifestations of various genetic disorders, the prenatal diagnosis of hemoglobinopathies, and the implementation and evaluation of newborn screening programs.

- Samuel Charache, MD
- Professor, Departments of Medicine and Pathology
- Johns Hopkins University

Dr. Charache is a Professor of Medicine and Pathology at The Johns Hopkins University School of Medicine. He also serves as Director of the Hematology Division, Department of Laboratory Medicine at Johns Hopkins Hospital. He has long been interested in hemoglobinopathies and has published numerous papers describing the laboratory and clinical aspects of newly identified hemoglobins and the pathogenesis and clinical manifestations of sickle cell disease. Dr. Charache has served as a member of the hematology study section of the National Institutes of Health, as a consultant to the Sickle Cell Disease Branch, NIH, as chairman of the Blood Diseases and Resources Committee of the National Heart, Lung, and Blood Institute, and as chairman of the American Society of Hematology Committee on Clinical Laboratory Standards, as well as the Society's representative to the National Committee on Clinical Laboratory Standards.

- Melvin Gerald, MD, MPH
- President and Chief Executive Officer
- Gerald Family Care Associates, P.C.

Dr. Gerald is Chairman, Department of Family Practice at Providence Hospital, Washington, DC, a Clinical Assistant Professor of Community Health and Family Practice at Howard University, and a Clinical Assistant Professor, Georgetown University. A fellow of the American Academy of Physicians, he is actively engaged in private practice and has served as Vice-Chairman of the Medicare/Medicaid Committee of the Medical Society of the District of Columbia.

- Serena K. Gilbert, MSW
- Director, Department of Social Work
- Prince George's Hospital Center

Ms. Gilbert is a certified clinical diplomate of social work who was formerly social work coordinator for the Howard University Center for Sickle Cell Disease. She presently serves as a consultant to the Center and to the Sickle Cell Support Association of the Metropolitan Areas (Washington, DC), and the National Institutes of Health. She is also a field instructor at the Howard University School of Social Work and the University of Maryland School of Social Work. She has published articles on the impact of social support on chronic illness in children, the health insurance plight of persons with sickle cell disease, and coping with death in children with sickle cell disease.

- Thomas R. Kinney, MD, Co-chair
- Professor of Pediatrics
- Duke University

Dr. Kinney is a Professor of Pediatrics at Duke University where he serves as Co-Director of the Duke-UNC Comprehensive Sickle Cell Center and as Director of Pediatric Graduate Education. He has been actively involved in the development of newborn screening for hemoglobinopathies in North Carolina and is a consultant for several pediatric sickle cell clinics in his State. He has published numerous articles on pediatric manifestations of sickle cell disease and other topics in pediatric hematology. Dr. Kinney is presently the principal investigator of several NIH-funded grants related to clinical research in sickle cell disease, including those that are focused on the natural history of the disease and the role of prophylactic penicillin in children with the disease who are older than 5 years of age.

- David Phoenix, DrPH
- Associate Professor of Community Health and Preventive Medicine
- Morehouse School of Medicine

Dr. Phoenix is an educator, researcher, and consultant in health policy and administration who has served on the faculty of several universities. He has conducted research on the development of a self-care protocol for adults with sickle cell disease, the Arizona health care cost-containment system, and the training, education, research, and service standards for multidisciplinary training programs for professionals providing services to the developmentally disabled and mentally retarded. He also has served as a consultant to the Psychosocial Research Division of the Duke University Comprehensive Sickle Cell Center, the Health Services Research Center of the University of North Carolina, and the Legal Aid Society of North Carolina. He has lectured extensively on self care in adults with sickle cell disease.

- Jeanne A. Smith, MD, MPH, Co-chair
- Associate Professor of Clinical Medicine
- Columbia University

Dr. Smith is an Associate Professor of Clinical Medicine at Columbia University and Director of the Comprehensive Sickle Cell Center at Harlem Hospital Center. An internist and hematologist, she is also chairman of the Executive Committee of the Cooperative Study of Sickle Cell Disease, an NIH-funded prospective study. Dr. Smith has also served on the Advisory Committee to the Division of Blood Diseases and Resources of the National Heart Lung and Blood Institute of the National Institutes of Health and as a member of the board of directors of the National Association for Sickle Cell Disease.

- Elliott Vichinsky, MD
- Associate Adjunct Professor of Pediatrics
- University of California, San Francisco

Dr. Vichinsky is the Associate Medical Director, Department of Hematology/Oncology at the Children's Hospital Medical Center, Oakland, CA. He also is director of the sickle cell program at that institution. He is an Associate Professor, University of California Medical Center, San Francisco. Currently, he is principal investigator of a collaborative study of preoperative transfusion in sickle cell disease. His publications include articles on the diagnosis of sickle cell disease, pain management, use of pneumococcal vaccine, penicillin prophylaxis, and nutritional deficiency in sickle cell disease.

- Ruby LaVerne Wesley, PhD, RN
- Assistant Professor of Nursing
- Wayne State University

Dr. Wesley is co-project director for a long-term training grant in rehabilitation nursing at Wayne State University and has conducted research and lectured on rehabilitation following violence-related spinal cord injury. She has published and presented on social support and health outcomes associated with sickle cell disease, psychosocial factors of sickle cell disease, and the role of social support.

- Doris L. Wethers, MD
- Professor of Clinical Pediatrics
- Columbia University

Dr. Wethers, a pediatrician, is Director of the Comprehensive Sickle Cell Program at St Luke's/Roosevelt Hospital Center in New York and a Professor of Clinical Pediatrics at Columbia University, College of Physicians and Surgeons. She also is Director of Pediatrics for the Manhattan Medical Group (HIP). She has had a long-standing interest in sickle cell disease and has published numerous articles on sickle cell screening programs and the clinical aspects of the disorder. She served as chairman of the NIH Consensus Conference on Newborn Screening for Sickle Cell Disease and Other Hemoglobinopathies and currently is co-chair of the New York State Sickle Cell Implementation Committee.

- Charles F. Whitten, MD
- Associate Dean, School of Medicine
- Wayne State University

Dr. Whitten is a Distinguished Professor of Pediatrics and Associate Dean for Curricular Affairs at Wayne State University School of Medicine and Director of the Comprehensive Sickle Cell Center at that institution. A pediatrician, he has major interests in nutrition and the growth and development of children and in sickle cell disease. He has lectured and published on several aspects of sickle cell disease including evaluation of genetic counseling and the provision of support to address the psychosocial needs of families. He is co-editor of the New York Academy of Medicine proceedings of a symposium on sickle cell disease. In 1971, he founded the Sickle Cell Detection and Information Center in Detroit, which is the only community organization that conducts a State-wide sickle cell newborn screening and followup program. In 1973 he was a founder and for 19 years served as president of the National Association for Sickle Cell Disease, an organization of over 70 community groups in the United States devoted to the provision of screening, education, counseling, and clinical services to individuals and families with sickle cell disease and trait and to advocacy for national programs which would provide these services.

- Iola Williams, RN, PNP
- Coordinator, Sickle Cell Program
- Children's National Medical Center

Mrs. Williams has been coordinator of the Sickle Cell Program at Children's National Medical Center, Washington, DC, since 1972. In this role, she has been responsible for the organization of the clinic which currently has a registration of almost 700 patients. In addition to serving as a patient advocate, she has been an active participant in research and is currently participating in the Cooperative Study of Sickle Cell Disease. She is a founder of the International Association of Sickle Cell Nurses and Physicians' Assistants.