# Glossary

Acute splenic sequestration crisis: The trapping of red cells in the spleen, leading to acute worsening of anemia, splenomegaly, and the potential for shock, vascular collapse, and death.

Anemia: Any condition in which there is a reduction of hemoglobin concentration below the normal range; can have many causes other than hemoglobinopathies.

Beta-thalassemia trait: A condition in which an individual inherits a normal beta globin gene and a beta globin gene that results in reduced synthesis of normal beta globin.

Compound heterozygote: Individual who has inherited two different abnormal genes for a characteristic.

Cord blood: Blood from an infant's umbilical cord.

Genotype: The genetic composition of an individual.

Hand-and-Foot Syndrome: Painful swelling of the hands and feet in patients with sickle cell disease.

Hemoglobin: A protein found in red cells that is responsible for the transport of oxygen. The protein consists of two pairs of globin chains with a heme moiety attached to each chain.

Hemoglobin AA: The normal hemoglobin genotype.

Hemoglobin AS: The hemoglobin genotype of an individual who has inherited a normal beta globin gene from one parent and a betas globin gene from the other parent. This genotype is also known as sickle cell trait.

Hemoglobin AC: The hemoglobin genotype of an individual who has inherited a normal beta globin gene from one parent and a beta C globin gene from the other. This genotype also is called hemoglobin C trait.

Hemoglobin D, E, G, O: Other abnormal hemoglobins.

Hemoglobin F: The predominant hemoglobin found in the fetus. The amount of Hb F decreases after birth and is found in only small amounts in children and adults.

Hemoglobin SC: The hemoglobin genotype of an individual with sickle cell disease who has inherited a betas globin gene from one parent and a beta C globin gene from the other.

Hemoglobin SS: The hemoglobin genotype of an individual who has inherited a betas globin gene from each parent.

Hemoglobinopathy: A generic term for inherited disorders of hemoglobin structure.

Heterozygote: Individual who has inherited two different genes for a characteristic.

Homozygote: Individual who has inherited the same gene for a characteristic from both parents (these genes may be normal or abnormal).

Painful episode: An acute episode of pain affecting one or multiple body sites which occurs in individuals with sickle cell disease.

Phenotype: The observed appearance of a characteristic. (This may differ from the genotype.)

Sickle beta-thalassemia (S B-thalassemia): A disorder resulting from the inheritance of a sickle (S) gene from one parent and a beta-thalassemia gene from the other. Conditions in this group are also designated as "+" or "o," depending on the severity of the synthetic defect. In the "+" type some normal beta chain is produced. In the "o" type, no normal beta globin is produced.

Sickle cell anemia: The hemoglobinopathy resulting from the inheritance of two betas globin genes (SS).

Sickle cell disease: A group of diseases characterized by the production of Hb S resulting from the inheritance of two betas globin genes (Hb SS), a beta S and a beta C gene (Hb SC), a beta S and a beta-thalassemia gene (Hb S beta-thalassemia), or a beta S gene and a gene for other abnormal hemoglobin which polymerizes with Hb S.

Sickle cell preparation (Metabisulfite): A test that identifies the presence of a sickling hemoglobin.

Solubility test: A test using dithionate to identify the presence of sickling hemoglobin.

Two-tier-system: A testing strategy where the presence of an abnormal hemoglobin identified by one technique is confirmed by a second test.

Unstable hemoglobin: An abnormal hemoglobin that denatures under normal conditions.