# Acronyms

ABMG: American Board of Medical Genetics

AG: Agar gel

AHCPR: Agency for Health Care Policy and Research

a: Alpha

ASSC: Acute splenic sequestration crisis

B: Beta

Bs: Beta S

CA: Cellulose acetate

CDC: Centers for Disease Control

Cit Ag: Citrate agar electrophoresis

CLIA: Clinical Laboratory Improvement Act

CORN: Council of Regional Networks for Genetic Services

DNA: Deoxyribonucleic acid

Hb: Hemoglobin

Hb AS: Hemoglobin A and S (sickle cell trait)

Hb F: Fetal hemoglobin

Hb S: Hemoglobin S (sickle hemoglobin)

Hb SC: Hemoglobin SC disease

Hb SS: Hemoglobin SS (sickle cell anemia)

HMO: Health maintenance organization

HPFH: Hereditary persistence of fetal hemoglobin

HPLC: High performance liquid chromatography

IEF: Isoelectric focusing

ISQAL: Centers for Disease Control Hemoglobinopathy Quality Control Program

NCCLS: National Committee for Clinical Laboratory Standards

NIH: National Institutes of Health

PKU: Phenylketonuria

RNA: Ribonucleic acid

WIC: Women, Infants, and Children Program