# References

## Overview

Emond AM, Collis R, Darvill D, et al. Acute splenic sequestration in homozygous sickle cell disease: natural history and management. J Pediatr 1985 Aug;107(2): 201-6.
Gilman PA, McFarlane JM, Huisman THJ. Natural history of sickle cell anemia: re-evaluation of a 15-year cord blood testing program [Abstract 452]. Pediatr Res 1976;10:376.
National Sickle Cell Anemia Control Act of 1972, 42, U.S.C., S 201.
Pearson HA, Gallagher D, Chilcote R, et al. Developmental pattern of splenic dysfunction in sickle cell disorders. Pediatrics 1985 Sep;76(3):392-7.
Schneider RG, Gustafson LP, Haggard ME. The incidence of genetically determined abnormalities in 11,427 cord blood samples. Presented at the 13th International Congress of Hematology, August 1970.
Scott RB. Health care priority and sickle cell anemia: special communication. JAMA 1970;214:731-4.

## Population To Be Screened

Anyane-Yeboa K. Hemoglobinopathy screening during early pregnancy. Pediatrics 1989 May;83(5 Pt 2):881-3.
Barnes MG, Komarmy L, Novack AH. A comprehensive screening program for hemoglobinopathies. JAMA 1972 Feb 7;219(6):701-5.
Broghamer WL Jr., Lockwood WB, Keeling MM. Clinical assessment of three hemoglobin screening programs on a selected population. South Med J 1981 Dec;74(12):1443-6.
Carr CM, Chapatwala KD. Sickle gene frequency in a Southcentral Alabama family medical program. Alabama Med 1988 Oct;58(4):17-8.
Castro O, Winter WP, Lee TCK, et al. Prevalence of a-chain variants at birth. Am J Clin Pathol 1981 Jan;75(1):56-9.
Diaz-Barrios V. New York's experience. Pediatrics 1989 May;83(5 Pt 2);872-5.
Eddy DM, Hasselblad V. FAST*PRO software for meta-analysis by the confidence profile method. San Diego: Academic Press; 1992.
Foster K, Forbes M, Hayes R, et al. Cord blood screening for sickle hemoglobin: evidence against a female preponderance of hemoglobin S. South J Pediatr 1981 Jan;98(1):79-81.
Frame PS. A critical review of adult health maintenance, part 1: prevention of atherosclerotic diseases. J Fam Pract 1986;22:341.
Gardner RV, Keitt A. University of Florida sickle cell screening program for neonates: design and results. J Natl Med Assoc 1988 Mar;80(3):273-9.
Gaston MH, Verter JL, Woods G, et al. Prophylaxis with oral penicillin in children with sickle cell anemia: a randomized trial. N Engl J Med 1986;314:1593-9.
Grover R, Wethers DL, Shahidi S, et al. Evaluation of the expanded newborn screening program in New York City. Pediatrics 1978;61:740-9.
Harris MS, Eckman JR. Georgia's experience with newborn screening: 1981 to 1985. Pediatrics 1989 May;83(5 Pt 2):858-60.
Huisman THJ, Harris HF, Stewart A, et al. The frequencies of Hbs S and C in Georgia and South Carolina. Hum Genet 1991;87:102-3.
Lane PA, Mauro RD, Houston ML, et al. Universal neonatal screening for hemoglobinopathies is more cost-effective than screening targeted to high-risk infants [Abstract]. Presented at the Ninth National Neonatal Screening Symposium, Raleigh, NC, April 7-11, 1992.
Lobel JS, Cameron BF, Johnson E, et al. Value of screening umbilical cord blood for hemoglobinopathy. Pediatrics 1989 May;83(5 Pt 2):823-6.
Mack A. Florida's experience with newborn screening. Pediatrics 1989 May;83 (5 Pt 2);861-3.
Meany FJ, Riggle SM. Newborn screening report, 1990. Austin (TX): Council of Regional Networks for Genetic Services; 1992.
Pass KA, Gauvreau AF, Schedlbauer LM, et al. Newborn screening for sickle cell disease in New York State. In Carter TP, Wiley AM, editors. Genetic disease: screening and management. New York: AR Liss; 1986. p. 359-72.
Pearson HA. The kidney, hepatobiliary system, and spleen in sickle cell anemia. Sickle cell disease. Ann N Y Acad Sci 1989;565:120-5.
Powars DR. Diagnosis at birth improves survival of children with sickle cell anemia. Pediatrics 1989;83(Suppl):830-3.
Ralston KK, Kmetz DR, Keeling MM, et al. Screening for major hemoglobinopathies in newborn blacks. J Ky Med Assoc 1981 Oct;79(10):649-51.
Schedlbauer LM, Pass KA. Cellulose acetate/citrate agar electrophoresis of filter paper hemolysates from heel stick. Pediatrics 1989 May;83(5 Pt 2):839-42.
Sickle Cell Disease Guideline Panel. Sickle cell disease. Guideline report. AHCPR Pub. No. 93 0504. Rockville (MD): Agency for Health Care Policy and Research; in press.
Sprinkle RH, Hynes DM, Konrad TR. A reconsideration of universal neonatal hemoglobinopathy screening in the United States; in press.
Therrell BL, Simmank JL, Wilborn M. Experiences with sickle hemoglobin testing in the Texas newborn screening program. Pediatrics 1989 May;83(5 Pt 2);864-7.
Tsevat JW, John B, Wong J, Pauker SG, et al. Neonatal screening for sickle cell disease: a cost-effectiveness analysis. J Pediatr 1991 April;118(4 Pt 1):546-54.
Vichinsky E, Hurst D, Earles A, et al. Newborn screening for sickle cell disease: effect on mortality. Pediatrics 1988 Jun;81(6):749-55.
Wethers DL, Grover R. Screening the newborn for sickle cell disease: is it worth the effort. In: Carter TP, Wiley AM, eds, Genetic disease: screening and management. Proceedings of the 1985 Albany Birth Defects Symposium. New York: Alan R. Liss; 1986. p. 123-136.

## Laboratory Screening for Sickle Cell Disease

Adam B, Bell C. Performance surveillance: sickle cell disease and other hemoglobinopathies. Infant Screening Quality Assurance Program 1992;2:1-8.
Broghamer WL Jr., Lockwood WB, Keeling MM. Clinical assessment of three hemoglobin screening programs on a selected population. South Med J 1981 Dec;74(12):1443-6.
Chan MS, Schneider NJ. Laboratory screening of hemoglobinopathies. Health Lab Sci 1975 Apr;12(2):91-9.
Clinical Laboratories Improvement Amendments of 1988, 42, U.S.C., S 201. . Clinical Laboratories Improvement Amendments of 1988, 42, U.S.C., S 201.
Descartes M, Huang Y, Zhang YH, et al. Direct genotypic analysis for sickle cell disease using DNA from newborn screening specimens: correlation with results from the state laboratory. Joint meeting of the American Pediatric Society for Pediatric Research, Anaheim CA, May 7-10, 1990. [Abstract] Pediatr Res 1990;27(4 part 2):130A.
Fleiss JL. Statistical methods for rates and proportions. New York: Wiley; 1981.
Galacteros F, Kleman K, Caburi-Martin J, et al. Cord blood screening for hemoglobin abnormalities by thin layer isoelectric focusing. Blood 1980;56: 1068-71.
Gardner RV, Keitt A. University of Florida sickle cell screening program for neonates: design and results. J Natl Med Assoc 1988 Mar;80(3):273-9.
Garrick M, Dembure P, Guthrie R. Sickle-cell anemia and other hemoglobinopathies: procedures and strategy for screening employing spots of blood on filter paper as specimens. N Engl J Med 1973 Jun;288(24):1265-8.
Githens JH, Lane PA, McCurdy RS, et al. Newborn screening for hemoglobinopathies in Colorado. Am J Dis Child 1990 Apr;144(4):466-70.
Griffiths PD, Mann Jr., Darbyshire PJ, et al. Evaluation of eight and a half years of neonatal screening for hemoglobinopathies in Birmingham. BMJ [Clin Res Ed] 1988 Jun;296:1583-5.
Hicks EJ, Hughes BJ. Comparison of electrophoresis on citrate agar, cellulose acetate, or starch for hemoglobin identification. Clin Chem 1975;21(8):1072-6.
Huisman THJ. Usefulness of cation exchange high performance liquid chromatography as a testing procedure. Pediatrics 1989;83(Suppl):849-51.
Huntsman RG, Metters JS, Yawson GI. The diagnosis of sickle cell disease in the newborn infant. J Pediatr 1972;80:279-81.
Jacobs S, Peterson L, Thompson L, et al. Newborn screening for hemoglobin abnormalities. A comparison of methods. Am J Clin Pathol 1986;85:713-5.
Kinney TR, Sawtschenko M, Whorton M, et al. Techniques' comparison and report of the North Carolina experience. Pediatrics 1989;83(Suppl):843-8.
Kleman KM, Lorey FW, unpublished data, 1992. . Kleman KM, Lorey FW, unpublished data, 1992.
Kleman KM, Vichinsky E, Lubin BH. Experience with newborn screening using isoelectric focusing. Pediatrics 1989;83(Suppl):852-4.
Kramer MS, Rooks Y, Johnston D, et al. Accuracy of cord blood screening for hemoglobinopathies. JAMA 1979;241:485-6.
Lobel JS, Cameron BF, Johnson E, et al. Value of screening umbilical cord blood for hemoglobinopathy. Pediatrics 1989 May;83(5 Pt 2):823-6.
McMahon L, unpublished data, 1992. . McMahon L, unpublished data, 1992.
Meany FJ, Riggle SM. Newborn screening report, 1990. Austin (TX): Council of Regional Networks for Genetic Services; 1992.
Miller ST, Stilerman TV, Rao SP, et al. Newborn screening for sickle cell disease: when is an infant lost to follow-up? Am J Dis Child 1990 Dec;144(12):1343-5.
National Committee for Clinical Laboratory Standards. Blood collection on filter paper for neonatal screening programs (NCCLS Doc. No. LA4-A). Villanova (PA): National Committee for Clinical Laboratory Standards; 1988.
Pass KA, Gauvreau AF, Schedlbauer LM, et al. Newborn screening for sickle cell disease in New York State. In Carter TP, Wiley AM, editors. Genetic disease: screening and management. New York: AR Liss; 1986. p. 359-72.
Rowley PT. Newborn screening for hemoglobinopathies. Semin Perinatol 1990 Dec;14:483-7.
Schedlbauer LM, Pass KA. Cellulose acetate/citrate agar electrophoresis of filter paper hemolysates from heel stick. Pediatrics 1989 May;83(5 Pt 2):839-42.
Schmidt RM, Brosius EM, Holland S, et al. Use of blood specimens collected on filter paper in screening for abnormal hemoglobin. Clin Chem 1976;22:685-7.
Schroeder WA, Jakway J, Powars D. Detection of hemoglobin S and C at birth: a rapid screening procedure by column chromatography. J Lab Clin Med 1975;82:304-8.
Steinberg MH, editor. Newborn screening for hemoglobinopathies: program development and laboratory methods. Bethesda (MD): National Heart, Lung, and Blood Institute; 1990.
Therrell BL, Panny SR, Davidson A, et al. Newborn screening system guidelines. Statement of the Council of Regional Networks for Genetic Services. Austin (TX): Council of Regional Networks for Genetic Services; 1990. p. 1-10.

## Medical Management of Newborns and Infants with Sickle Cell Disease

Therrell BL, Pass KA, Hassemer D, et al. Laboratory techniques for neonatal hemoglobinopathy screening. Austin (TX): Texas Department of Health; 1990.
Adams T, McKie V, Nichols F, et al. The use of transcranial ultrasonography to predict stroke in sickle cell disease. N Engl J Med 1992 Feb;326:605-10.
Anglin DL, Siegel JD, Pacini DL. Effect of penicillin prophylaxis on nasopharyngeal colonization with Streptococcus pneumoniae in children with sickle cell anemia. J Pediatr 1984 Jan;104(1):18-22.
Bainbridge R, Higgs DR, Maude GH, et al. Clinical presentation of homozygous sickle cell disease. J Pediatr 1985 Jun;106(6):881-5.
Bakshi SS, Grover R, Cabezon E, et al. Febrile episodes in children with sickle cell disease treated on an ambulatory basis. J Assoc Acad Minor Phys 1991;2(2): 80-3.
Belgrave FZ, Molock SD. The role of depression in hospital admissions and emergency treatment of patients with sickle cell disease. J Natl Med Assoc 1991 Sep;83(9):777-81.
Brown AK, Miller ST, Agatisa P. Care of infants with sickle cell disease. Pediatrics 1989 May;83(5 Pt 2):897-900.
Buchanan GR, Schiffman G. Antibody responses to polyvalent pneumococcal vaccine in infants with sickle cell anemia. J Pediatr 1980 Feb;96(2):264-6.
Buchanan GR, Siegel JD, Smith SS, et al. Oral penicillin prophylaxis in children with impaired splenic function: a study of compliance. Pediatrics 1982 Dec;70(6): 926-30.
Buchanan GR, Smith SJ. Pneumococcal septicemia despite pneumococcal vaccine and prescription of penicillin prophylaxis in children with sickle cell anemia. Am J Dis Child 1986 May;140(5):428-32.
Centers for Disease Control. Risk associated with human parvovirus B19 infection. MMWR 1989;38:81-97.
Chudwin DS, Wara DW, Matthay KK. Increased serum opsonic activity and antibody concentration in patients with sickle cell disease after pneumococcal polysaccharide immunization. J Pediatr 1983 Jan;102(1):51-4.
Consensus Conference. Newborn screening for sickle cell disease and other hemoglobinopathies. JAMA 1987 Sep;258(9):1205-9.
Cummins D, Heuschkel R, Davies SC. Penicillin prophylaxis in children with sickle cell disease in Brent study of physicians knowledge, patient compliance. BMJ 1991 Apr;302:989-90.
Davies SC, Brozovic M. The presentation, management, and prophylaxis of sickle cell disease. Blood Rev 1989;3:29.
Day S, Brunson G, Wang W. A successful education program for parents of infants with newly diagnosed sickle cell disease. J Pediatr Nurs 1992;7(1):52-7.
De Ceulaer K, McMullen KW, Maude GH, et al. Pneumonia in young children with homozygous sickle cell disease: risk and clinical features. Eur J Pediatr 1985 Sep;144(3):255-8.
Enwonwu CO. Nutritional support in sickle cell anemia: theoretical considerations. J Natl Med Assoc 1988 Feb;80(2):139-44.
Flanagan C. Home management of sickle cell anemia. Pediatr Nurs 1980 Mar-Apr; 6(2):A-D.
Gaston MH, Verter JL, Woods G, et al. Prophylaxis with oral penicillin in children with sickle cell anemia: a randomized trial. N Engl J Med 1986;314: 1593-9.
Gigliotti F, Feldman S, Wang WC. Serologic follow-up of children with sickle cell disease immunized with Haemophilus influenzae type b conjugate vaccine during early infancy. J Pediatr 1991 Jun;118(6):917-9.
Givner LB, Luddy RE, Schwartz AD. Etiology of osteomyelitis in patients with major sickle hemoglobinopathies. J Pediatr 1981 Sep;99(3):411-3.
Graff-Lonnevig V, Hedlin G, Lindfors A. Penicillin allergy: a rare pediatric condition? Arch Dis Child 1988 Nov;63(11):1342-6.
Grover R, Shahidi S, Fisher B, et al. Current sickle cell screening program in New York City. Am J Public Health 1983 March;73:249-53.
Hales K, Barriere S. Polyvalent pneumococcal vaccine. A review. Am J Hosp Pharm 1979 Jun;36(6):773-7.
International Rheumatic Fever Study Group. Allergic reaction to long term benzathine penicillin prophylaxis for rheumatic fever. Lancet 1991 June 1;337: 1308-10.
John AB, Ramlal A, Jackson H, et al. Prevention of pneumococcal infection in children with homozygous sickle cell disease. BMJ 1984;288:1567-70.
Kaplan EC, Berrios X, Speth J, et al. Pharmacokinetics of benzathine penicillin serum levels during the 28 days after IM injection of 1.2 IU. J Pediatr 1989 Jul;115:146-50.
Kim HC, Alavi A, Russell M, et al. Differentiation of bone and bone marrow in infants from osteomyelitis in sickle cell diseases. Clin Nucl Med 1989 Apr;141: 249-54.
Leikin SL, Gallagher D, Kinney TR. Mortality in children and adolescents with sickle cell disease. Pediatrics 1989 Sep;84:500-8.
Listernick R, Frisone L, Silverman BL. Delayed diagnosis of infection with abnormal neonatal screens. JAMA 1992 Feb;267(8):1095-9.
Lobel JS, Cameron BF, Johnson E, et al. Value of screening umbilical cord blood for hemoglobinopathy. Pediatrics 1989 May;83(5 Pt 2):823-6.
Marcinak JF, Frank AL, Labotka RL, et al. Haemophilus influenzae type b vaccine in children with sickle cell disease. Antibody persistence after vaccination at age one and one half to six years. Pediatr Infect Dis J 1991 Feb;10(2):157-9.
McIntosh S, Rooks Y, Ritchey AK, et al. Fever in young children with sickle cell disease. J Pediatr 1980;96:199-204.
Miller ST, Stilerman TV, Rao SP, et al. Newborn screening for sickle cell disease: when is an infant lost to follow-up? Am J Dis Child 1990 Dec;144(12):1343-5.
Ndumbe PM, Nyouma E. Transmission of hepatitis B virus by blood transfusion in Yaounde, Cameroon. BMJ 1990 Sep;301:523-4.
Nussbaum RL, Powell C, Graham HL, et al. Newborn screening for sickling hemoglobinopathies. Houston, 1976 to 1980. Am J Dis Child 1984 Jan;138(1): 44-8.
O'Brien RT, McIntosh S, Aspnes GT, et al. Prospective study of sickle cell anemia in infancy. J Pediatr 1976 Aug;89(2):205-10.
Ohene-Frempong K. Stroke in sickle cell disease: demographic, clinical and therapeutic considerations. Semin Hematol 1991 Jul;28(3):213-9.
Overturf GD. Pneumococcal vaccination: update and evaluation. Prog Clin Biol Res 1982;98:59-71.
Overturf GD, Powars D, Baraff LJ. Bacterial meningitis and septicemia in sickle cell disease. Am J Dis Child 1977 Jul;131(7):784-7.
Pavlakis SG, Prohovnik I, Piomelli S, et al. Neurologic complications of sickle cell disease [Retraction of Barness LA]. Adv Pediatr 1989;36:247-76.
Pearson HA.1986;
Pearson HA, Cobb WT. Folic acid studies in sickle cell anemia. J Lab Clin Med 1964 Dec;64:913-21.
Pegelow CH, Armstrong FD, Light S, et al. Experience with the use of prophylactic penicillin in children with sickle cell anemia. J Pediatr 1991 May; 118(5):736-8.
Powars DR. Natural history of sickle cell disease: first 10 years. Semin Hematol 1975;12(3):267-85.
Powars DR, Overturf G, Weiss J, et al. Pneumococcal septicemia in children with sickle cell anemia: changing trend of survival. JAMA 1981 May;245(18):1839-42.
Rogers ZR, Morrison RA, Vedro DA, et al. Outpatient management of febrile illness in infants and young children with sickle cell anemia. J Pediatr 1990 Nov;117(5):736-9.
Rowley PT, Huntzinger DJ. Newborn sickle cell screening. Benefits and burdens realized. Am J Dis Child 1983 Apr;137(4):341-5.
Seeler RA, Metzger W, Mufson A. Diplococcus pneumoniae infections in children with sickle cell anemia. Am J Dis Child 1972 Jan;123(1):8-10.
Seeler RA, Shwiaki MZ. Acute splenic sequestration crisis in young children with sickle cell anemia. Clinical observations in 20 episodes in 14 children. Clin Pediatr 1972 Dec;11(12):701-4.
Serjeant GR. Treatment of sickle cell disease in early childhood in Jamaica. Am J Pediatr Hematol Oncol 1985 Fall;7(3):235-9.
Sills R. Splenic function: physiology and splenic hypofunction. Crit Rev Oncol Hematol 1987;7:1-36.
Spirer Z. The role of the spleen in immunity and infection. Adv Pediatr 1980;27: 55-88.
Thurn J. Human parvovirus B19: historical and clinical review. Rev Inf Dis 1988 Sep-Oct;10(5):1005-11.
Topley JM, Rogers DW, Stevens MC, et al. Acute splenic sequestration and hypersplenism in the first five years in homozygous sickle cell disease. Arch Dis Child 1981;56:765-9.
Vichinsky E, Hurst D, Earles A, et al. Newborn screening for sickle cell disease: effect on mortality. Pediatrics 1988 Jun;81(6):749-55.
Vichinsky E, Lubin BH. Suggested guidelines for the treatment of children with sickle cell anemia. Hematol Oncol Clin North Am 1987 Sep;1(3):483-501.
Warren NS, Carter TP, Humbert Jr., et al. Newborn screening for hemoglobinopathies in New York State. Experience of physicians and parents of affected children. J Pediatr 1982 Mar;100(3):373-7.
Webb DK, Serjeant GR. Systemic salmonella infections in sickle cell anaemia. Ann Trop Paediatr 1989 Sep;9(3):169-72.
Wethers DL, unpublished data, 1992. Wethers DL, unpublished data, 1992.
Whitten CF. Newborn screening for sickle cell disease and other hemoglobinopathies. Perspective from the National Association for Sickle Cell Disease. Pediatrics 1989 May;83(5 Pt 2):906-7.
Wright L, Brown A, Davidson-Mundt A. Newborn screening: the miracle and the challenge. J Pediatr Nurs 1992;7(1):26-42.
Zarkowsky HS, Gallagher D, Gill FM, et al. Bacteremia in sickle hemoglobinopathies. J Pediatr 1986 Oct;109(4):579-85.

## Educating and Counseling Parents of Newborns with Sickle Cell Disease and Trait

American Society of Human Genetics. Membership Directory, 1992-1993. Bethesda, MD: American Society of Human Genetics, Genetics Society of America, and American Board of Medical Genetics; 1992.
Cantor AB, Miller MC III, Larisey L, et al. A study of media effectiveness for sickle cell anemia education in a rural community. J Natl Med Assoc 1979 Nov;71(11):1055-7.
Grossman LK, Holtzman NA, Charney E, et al. Neonatal screening and genetic counseling for sickle cell trait. Am J Dis Child 1985 Mar;139(3):241-4.
Loader S, Sutera CJ, Walden M, et al. Prenatal screening for hemoglobinopathies. II. Evaluation of counseling. Am J Hum Genet 1991;48:447-51.
Miller DR. Pitfalls of newborn screening for sickle cell anemia. Am J Dis Child 1979;133(12):1235-6.
Neal-Cooper F, Scott RB. Genetic counseling in sickle cell anemia: experiences with couples at risk. Public Health Rep 1988;103(2)174-8.
Rowley PT, Mack L Jr., Lawrence F. Screening and genetic counseling for beta-thalassemia trait in a population unselected for interest: comparison of three counseling methods. Am J Human Genet 1984;36:677-89.
St Clair L, Rosner F, James G. The effectiveness of sickle cell counseling. Am Fam Phys 1978 Apr;17(4):127-30.
Whitten CF, Thomas JF, Nishlura EN. Sickle cell trait counseling: evaluation of counselors and counselees. Am J Hum Genet 1981 Sep;33(5):802-16.
Zinberg R, Greendale K. Do we have a shortage of genetic counselors in New York State? Genesis 1991:3:3.