# Acknowledgments

Many organizations and individuals made significant contributions during the development of this guideline. They are too numerous to list here, but their assistance is appreciated. Peer reviewers, individuals at institutions that provided pilot review, and consultants are acknowledged individually in the contributors section.

All persons, organizations, and agencies with an interest in the sickle cell guideline were invited to participate at a public meeting held in Washington DC on September 24, 1991. The panel gratefully acknowledges the valuable input received.

The panel also wishes to acknowledge input from several Public Health Service agencies including the Food and Drug Administration, the Centers for Disease Control, and the Armed Forces Institute of Pathology.

Mary L. Grady, Center for Research Dissemination and Liaison, Agency for Health Care Policy and Research, edited the guideline and coordinated its production and publication.

Finally, the panel thanks Robert Sprinkle, MD, and Patience Ejiogu-Akinosho, MPA, MPH, for their untiring efforts as research coordinators. Dr. Sprinkle's contributions as a health policy analyst were particularly noteworthy.