# Panel Members

- Jeanne A. Smith, MD, MPH (Co-chair)
- Associate Professor of Clinical Medicine
- Columbia University
- Thomas R. Kinney, MD (Co-chair)
- Professor of Pediatrics
- Duke University
- Beverly Ames
- Consumer Representative
- Kwame Anyane-Yeboa, MD
- Associate Professor of Pediatrics
- Columbia University
- Samuel Charache, MD
- Professor of Medicine and Laboratory Medicine
- Johns Hopkins University
- Melvin Gerald, MD
- Family Physician
- Washington, DC
- Serena Gilbert, MSW
- Director, Department of Social Work
- Prince George's Hospital Center
- David Phoenix, DrPH
- Associate Professor of Community Health and Preventive Medicine
- Morehouse School of Medicine
- Ruby Laverne Wesley, PhD, RN
- Assistant Professor of Nursing
- Wayne State University
- Doris L. Wethers, MD
- Professor of Clinical Pediatrics
- Columbia University
- Charles Whitten, MD
- Associate Dean, School of Medicine
- Wayne State University
- Iola Williams, RN, PNP
- Coordinator, Sickle Cell Program Department of Hematology/Oncology
- Children's National Medical Center
- Elliot Vichinsky, MD
- Associate Adjunct Professor of Pediatrics
- University of California, San Francisco