# Foreword

Historically, sickle cell anemia the most common form of sickle cell disease has been associated with high mortality in early childhood due to overwhelming bacterial infections, splenic sequestration crisis, and the acute chest syndrome. Over the past 20 years, it has been recognized that comprehensive medical care could reduce morbidity and mortality in children with sickle cell anemia. In 1986, a double-blind, randomized, controlled clinical trial demonstrated that twice-daily doses of oral penicillin reduced mortality and morbidity from pneumococcal infections in children under 5 years of age with sickle cell anemia and sickle betao-thalassemia. A National Institutes of Health Consensus Conference on Newborn Screening concluded that screening could reduce morbidity and mortality, provided screening was linked to the provision of health care services.

Shortly after these findings were disseminated, neonatal sickle cell screening became widespread in the United States and now exists in more than 40 States. The development of these screening programs was stimulated by funds from the Bureau of Maternal and Child Health of the Public Health Service. The remarkable growth of these screening programs illustrates how Federal and State partnerships can dramatically improve the quality of health care.

There remain, however, many unresolved issues related to neonatal sickle cell screening. This guideline addresses these issues and provides specific recommendations for the implementation and conduct of a screening program based upon currently available scientific literature and, when such literature is lacking, the expert opinions of the panel members. .ti 20 Sickle Cell Disease Guideline Panel