# Guideline: Medical Management of Newborns and Infants with Sickle Cell Disease

The health care provider who is notified that a newborn has a positive screening test for sickle cell disease has the responsibility of promptly establishing a definitive diagnosis. Parents of affected infants should be educated about the disease, the importance of ongoing care, and the critical role they can play in early detection and management of infections and complications.

The 1987 Consensus Development Conference on Newborn Screening for Sickle Cell Disease (Consensus Conference, 1987) concluded that newborn screening for sickle cell disease is essential. This conclusion was based on studies showing that prophylactic penicillin and comprehensive care provided by knowledgeable clinicians dramatically reduced mortality in sickle cell disease.

The Guideline Panel found clear, compelling evidence to support this conclusion. It is therefore imperative that the physician caring for the child with sickle cell disease establish a definitive diagnosis and provide appropriate education and counseling to the child's parents. When the infant is affected with Hb SS or Hb S Bo-thalassemia, prophylactic penicillin must be started by no later than 2 months of age. Since acceptable screening tests have a high degree of sensitivity and specificity, the infant who tests positive for sickle cell disease should be treated as a severely affected infant until a definitive diagnosis is established.

The Panel reviewed published evidence that early entry into care is difficult to achieve, especially for inner city families, in rural areas, and in other instances where families live far from the source of care (Listernick, Frisone, and Silverman, 1992 ; Miller, Stilerman, Rao, et al., 1990). The task is simplified if the parent is already familiar with the newborn screening program in their locality. In many followup programs, public health or community health nurses make the initial contact with parents of infants who have positive screening tests. The first contact is crucial in facilitating the family's involvement in comprehensive health care management (Wright, Brown, and Davidson-Mundt, 1992). If the newborn screening program provides a well-structured followup component, almost all newborns identified as affected can be entered expeditiously into care.

Since the original test is a screening test, the health care provider must establish a definitive diagnosis. Establishing a definitive diagnosis requires several steps, depending upon the hemoglobin phenotype identified by initial testing. In those instances where the type of sickle cell disease involves two abnormal Bglobins (Hb SE, Hb SD, Hb SOArab), the definitive diagnosis is established if the hemoglobin phenotype on a second sample is identical to the initial phenotype.

In those instances where the screening result has an FS phenotype, definitive diagnosis is more difficult because there are several different genotypes which have the FS phenotype in the newborn. Examples of the different genotypes include: sickle cell anemia ( B^s^/B^s^), Hb S Bo-thalassemia ( B^s^/B o), Hb S B+-thalassemia ( B^s^/ B+), and Hb S in association with the hereditary persistence of fetal hemoglobin.

Definitive diagnosis of the FS phenotype requires correlation with the infant's hemoglobin concentration, red cell indices, and red cell morphology. Definitive diagnosis can be facilitated by assessment of hemoglobin phenotype and quantities of Hb A2 and Hb F in the parents. Before the father is tested, the mother should be told that testing of the father may uncover non-paternity (Whitten, 1989). Methods for establishing the hemoglobin phenotype are discussed in the laboratory section of this guideline.

## Entry Into Care

The first visit to the health care provider is the occasion to explain in simple language the basic facts about sickle cell disease. These basics should include a discussion of the signs and symptoms of the disease, its pathophysiology, and its mode of inheritance. The provider must educate the family about the clinical course of the disease, including what to expect, what to do, when to call for help, and how to reach help quickly (Rowley, and Huntzinger, 1983 ; Warren, Carter, Humpert, et al., 1982). It is essential that the parents become knowledgeable about routine child care responsibilities, including the measurement of body temperature. Nursing personnel are usually able to provide instruction on home management (Day, Brunson, and Wang, 1992). Several articles by experienced clinicians stress the importance of educating the parent (Brown, Miller, and Agatisa, 1989 ; Vichinsky, and Lubin, 1987). The education provided by the physician, nurse, social worker, and when available, support groups will assist parents greatly in complying with care (Davies, and Brozovic, 1989 ; Pearson, 1986 ; Vichinsky, Hurst, Earles, et al., 1988). The focus of the educational effort must be to teach parents to avoid, anticipate, and recognize problems. The provider must be sensitive to the earliest signs of illness and the importance of preventive care. In addition, providers must display empathy and be accessible in order to establish a long-term relationship with the parent and child.

Children with sickle cell anemia and the S Bo-thalassemia genotype are anemic by the age of 2 to 3 months (Bainbridge, Higgs, Maude, et al., 1985 ; O'Brien, McIntosh, Aspnes, et al., 1976), although those with SC and S B+-thalassemia may maintain their hemoglobin and hematocrit levels in the normal or near normal range. The health care practitioner should establish the child's individual steady-state hematologic baseline by obtaining a complete blood count and reticulocyte count periodically during visits for health care maintenance. This type of information should be given to the parent in writing along with other essential information -- type of sickle cell disease and size of the spleen -- so that it is available to medical personnel in the event the child is treated on an emergency basis by other than the usual health care providers.

Even though a positive family history for sickle cell disease is often lacking, a detailed family history should be obtained and a pedigree developed. The health care provider must remember that the sickle cell trait is not linked to skin color and is found not only in persons from Africa, but also in persons whose heritage is from the Mediterranean basin, the Caribbean, Central and South America, the Arabian peninsula, and India.

The health care provider who first contacts the parents should explore with them where the child can best receive medical care once a definitive diagnosis of sickle cell disease is established. This care can be provided by a family physician, pediatrician, or pediatric hematologist knowledgeable about sickle cell disease. In addition, care should be provided at a site that parents can access easily.

The health care provider, regardless of specialty, should have ready access to a tertiary care facility with sophisticated clinical laboratory and blood-banking facilities and modern imaging equipment suitable for the pediatric patient. Ideally, the patient should receive routine pediatric care in the same facility that manages complications of the disease. A shared approach to comprehensive care by a primary care provider and a specialist is a very satisfactory way to provide quality health care.

## Penicillin Prophylaxis

Penicillin prophylaxis should begin by 2 months of age for infants with suspected sickle cell anemia, whether or not the definitive diagnosis has been established.

Data gathered during the 1970s and 1980s showed that comprehensive care of the child with sickle cell disease lowered morbidity and mortality because of expectant management and early diagnosis of complications (Grover, Shahidi, Fisher, et al., 1983 ; Lobel, Cameron, Johnson, et al., 1989 ; McIntosh, Rooks, Ritchey, et al., 1980 ; Nussbaum, Powell, Graham, et al., 1984 ; Pegelow, Armstrong, Light, et al., 1991 ; Powars, Overturf, Weiss, et al., 1981). Some of this evidence is summarized in Table 13.

Table 13. Mortality from pneumococcal sepsis in different clinical settings

Study group | Study | Setting | Sample | Incidence of sepsis | Deaths | Percent
No comprehensive care or early intervention | Powars, et al., 1981 | California | 182 | 23 | 8 | 34.8
No comprehensive care or early intervention | Vichinsky, et al., 1988 | California | 64 | 11 | 4 | 36.4
Comprehensive care and early intervention | Powars, et al., 1981 | California | 75 | 11 | 0 | 0.0
Comprehensive care and early intervention | Vichinsky, et al., 1988 | California | 55 | 10 | 1 | 10.0

The high level of Hb F at birth prevents the newborn's red cells from sickling. Over the ensuing months, however, the concentration of Hb F declines, usually reaching a level that is too low to offer protection by age 6 months. It should be emphasized, however, that like most pediatric milestones, there is no magic age; rather, it is a continuum, and the infant must be considered at risk for sickle cell-related complications by age 2 months.

The most serious infections and complications in sickle cell anemia are pneumococcal sepsis and sepsis/meningitis (Leikin, Gallagher, and Kinney, 1989 ; Overturf, Powars, and Baraff, 1977 ; Powars, 1975 ; Seeler, Metzger, and Mufson, 1972 ; Zarkowsky, Gallagher, Gill, et al., 1986). These complications occur at a frequency 400 to 500 times higher in children with sickle cell anemia than normal children and are usually heralded by significant fever (McIntosh, Rooks, Ritchey, et al., 1980 ; Powars, 1975).

The best immediate, intrinsic defenses to pneumococcal infection are the phagocytic cells and the endothelial macrophages that line the splenic cords. This defense is unavailable to the child with sickle cell anemia or sickle Bo-thalassemia, as splenic function is lost during the first 2 years of life due to the congestion of the spleen with sickled cells. This deficiency, as well as a lack of opsonins and defective complement activation via the alternate pathway, contributes to the infant's increased vulnerability to sepsis from encapsulated bacteria. Once infection with these organisms begins, events move with frightening swiftness. Death occurs in approximately 25 percent of cases. Two reviews on spleen function are particularly relevant to the child with sickle cell disease (Sills, 1987 ; Spirer, 1980).

The role of prophylactic penicillin as the cornerstone of management to reduce morbidity and mortality from S. pneumoniae was defined by Gaston, Verter, Woods, and colleagues . This landmark study involved a multi-institutional, randomized, double-blind, placebo-controlled group of children 3 months to 5 years of age who had sickle cell anemia. Children in the study under 3 years of age were given oral penicillin twice a day, 125 mg per dose; children over 3 years received 250 mg twice a day. There were approximately 100 children in each group. Penicillin was so effective in lowering both morbidity and mortality that the study was terminated prematurely.

A somewhat comparable controlled study had been carried out in Jamaica, using intramuscular benzathine penicillin (John, Ramlal, Jackson, et al., 1984). Children treated with this drug had significantly reduced mortality. Table 14 summarizes both of these studies.

Table 14. Morbidity and mortality in controlled trials of penicillin prophylaxis and pneumococcal vaccine in children with sickle cell disease

Study group | Study | Setting | Sample | Infections | | Deaths | | Person-years Followup
Study group | Study | Setting | Sample | No. | % | No. | % | Person-years Followup
Penicillin + Pn vaccine | John, et al., 1984 | Jamaica | 97 | 7 | 2.5 | 2 | 28.6 | 275
Pn vaccine only | John, et al., 1984 | Jamaica | 62 | 4 | 2.3 | 0 | 0.0 | 174
Penicillin + H. influenzae B | John, et al., 1984 | Jamaica | 46 | 0 | 0.0 | 0 | 0.0 | 106
H. influenzae B only | John, et al., 1984 | Jamaica | 27 | 2 | 3.8 | 0 | 0.0 | 106
Penicillin + Pn vaccine | Gaston et al., 1986 | U.S. multi-State | 105 | 2 | 1.9 | 0 | 0.0 | 131.25
Pn vaccine only | Gaston et al., 1986 | U.S. multi-State | 110 | 13 | 7.9 | 3 | 23.1 | 137.5

Note: Pn vaccine = Pneumococcal vaccine.

The U.S. study did not use benzathine penicillin because injections are painful, and it would have created major logistical problems to ensure that each child received the injection on time. Current evidence indicates that injections need to be given every 3 weeks to maintain effective blood levels of penicillin (Kaplan, Berrios, Speth, et al., 1989). It should be emphasized that benzathine penicillin injection is an appropriate option for individual patients when the family will keep appointments consistently.

Equally worthy of emphasis is that aggressive efforts must be made by the health care provider to ensure compliance with an oral penicillin program. The parent must be clear about the importance of the prophylactic penicillin, how to give it, and the potentially dire consequences if it is not administered. Until the child is eating solid foods, a liquid preparation can be prescribed. This must be stored in the refrigerator and discarded after 2 weeks. Once the child is eating solids, pills can be dispensed and the mother instructed how to crush and administer the medicine with applesauce, sherbet, or another appropriate food.

Long-term compliance with any therapeutic regimen is difficult and requires constant reminders and reinforcement (Flanagan, 1980). Even the landmark penicillin prophylaxis study (Gaston, Verter, Woods, et al., 1986) estimated only about 60 percent compliance. Other authors have noted similar levels of compliance and suggested means of improving it (Buchanan, Siegel, Smith, et al., 1982 ; Cummins, Heuschkel, and Davies, 1991 ; Pegelow, Armstrong, Light, et al., 1991). The nurse in the clinic and the public health nurse who visits the home are in a unique position to reinforce the importance of compliance with the prescribed regimen (Day, Brunson, and Wang, 1992).

Long-term penicillin administration has proven to be safe and relatively nontoxic, not only from observations of sickle cell children (Anglin, Siegel, and Pacini, 1984 ; Gaston, Verter, Woods, et al., 1986), but also through even longer experience with rheumatic fever prophylaxis (Graff-Lonnevig, Hedlin, and Lindfors, 1988 ; International Rheumatic Fever Study Group, 1991). For the rare child who is allergic to penicillin, erythromycin ethyl succinate, 20 mg per kilogram divided into two daily doses, can be substituted.

## Diagnosis and Management of Complications

Health care providers must educate parents about the early signs and symptoms of illness in the infant with sickle cell disease that require immediate medical attention. Also, health care providers must be aware of the urgency of promptly detecting and treating infections and other complications, including acute splenic sequestration, aplastic crisis, stroke, hand-and-foot syndrome, and acute chest syndrome.

The infant with sickle cell disease also is at risk for other life-threatening complications in addition to those related to bacterial infection. The practitioner must educate the parent about the importance of seeking medical advice when the infant exhibits signs and symptoms of illness, particularly temperature elevation greater than 101 degrees F (38.5 degrees C), changes in behavior (unusual somnolence or irritability), feeding disturbances (anorexia, vomiting, or diarrhea), pallor of mucus membranes, and/or rapid respirations.

The practitioner must approach fever in infants with sickle cell disease as an emergency. The importance of obtaining prompt medical consultation must be stressed to the parent. The suddenness of the appearance of sepsis and its high mortality rate have been well documented (Bainbridge, Higgs, Maude, et al., 1985 ; Powars, 1975 ; Seeler, Metzger, and Mufson, 1972). Health care workers must be aware of the importance of evaluating febrile sickle cell children promptly and the necessity for administering antibiotics that provide coverage for S. pneumoniae and H. influenzae.

The antibiotic should be given as soon as a blood culture is obtained (Bakshi, Grover, Cabezon, et al., 1991 ; Rogers, Morrison, Vedro, et al., 1990). This mandate should be followed even if the child is receiving penicillin prophylaxis. Several authors (Buchanan, and Smith, 1986 ; Wethers, 1992) have shown that sepsis can still occur despite the prescription of penicillin prophylaxis and administration of pneumococcal vaccine. This reinforces the need for continuing emphasis on compliance as well as constant alertness on the part of the doctors who care for these patients.

Fast or difficult breathing may indicate an Acute Chest Syndrome (ACS) -- that is, pulmonary involvement secondary to lung infarct or infection, alone, or in combination (De Ceulaer, McMullen, Maude, et al., 1985). ACS is a significant cause of mortality in children of all ages with sickle cell disease (Leikin, Gallagher, and Kinney, 1989). ACS usually requires hospitalization and, when indicated by hypoxemia or worsening anemia, administration of oxygen and/or red cell transfusion.

Acute splenic sequestration crisis is a potentially life-threatening complication of sickle cell disease. The child with acute splenic sequestration crisis has a sudden entrapment of a large portion of the blood volume in the spleen, with consequent cardiovascular compromise similar to that accompanying acute blood loss (Seeler, and Shwiaki, 1972 ; Topley, Rogers, Stevens, et al., 1981). The diagnosis is established by the findings of pallor, splenomegaly, and worsening anemia and when severe, signs of cardiovascular collapse. The reticulocyte count is elevated, and thrombocytopenia frequently is observed during a splenic sequestration crisis.

Since prompt recognition of a splenic sequestration crisis may be lifesaving, parents must be taught how to recognize increasing anemia and an enlarging spleen. Parents can learn to palpate the spleen or recognize secondary signs, such as increase in the abdominal girth or signs of abdominal pain. Treatment includes immediate restoration of blood volume by red cell transfusion. Table 15 shows the occurrence of acute splenic sequestration crisis, its mortality, and the effect of early identification on morbidity and mortality in the affected child.

Table 15. Incidence of splenic sequestration in children with sickle cell disease

Study group | Study | Setting | Sample | Patients/Episodes | Percent | Notes
Incidence of ASSC in sickle cell children in a comprehensive care program | Topley, et al., 1981 | Jamaica | 216 | 52/71 | 24.1
Incidence of ASSC in sickle cell children in a comprehensive care program | Brown, et al., 1989 | New York | 159 | 5/7 | 3.1
Study group | Study | Setting | ASS Episodes | Mortality | Percent | Notes
Incidence of fatal ASSC in sickle cell children in comprehensive care | Topley, et al., 1981 | Jamaica | 71 | 10 | 14.1 | Bacteremia Related
Incidence of fatal ASSC in sickle cell children in comprehensive care | Brown, et al., 1989 | New York | 5 | 1 | 20.0 | Bacteremia Related
Incidence of fatal ASSC in SS children not in a comprehensive care program | Seeler and Shwiaki, 1972 | Chicago | 14 | 4 | 28.6

An aplastic crisis, precipitated by a temporary arrest of red cell production in the bone marrow, is usually caused by parvovirus infection. Pallor, fatigue, or decreased activity are the principal signs and symptoms (Centers for Disease Control, 1989 ; Thurn, 1988). A blood count reveals a fall in the hemoglobin and hematocrit levels and reticulocytopenia. Although aplastic crises are transient, a red cell transfusion is indicated if the infant is symptomatic from the anemia.

Stroke is a relatively infrequent complication in the young infant that is caused by occlusion of cerebral vessels. The median age for the occurrence of stroke in children is 7 years. However, any loss of consciousness in a child with sickle cell disease of any age, and any dysfunction of an extremity whether or not it is painful, should be investigated immediately. A child who drags a foot or stops using a hand may have a neurologic deficit, rather than a guarding response to pain. The child with any degree of neurologic symptoms should be seen promptly (Pavlakis, Prohovnik, Piomelli, et al., 1989).

Table 15

Diagnostic procedures such as magnetic resonance imaging (MRI) of the brain and transcranial ultrasonography are useful in the evaluation of neurologic problems (Adams, McKie, Nichols, et al., 1992). If a thrombotic stroke has occurred, periodic red cell transfusions are the best therapy for preventing recurrence (Ohene-Frempong, 1991).

The most frequent initial complication of sickle cell disease is called hand-and-foot syndrome, or dactylitis. Signal symptoms include painful swelling of the hands and/or feet, which may or may not be symmetric. Often, there is evidence by x-ray findings of periosteal elevation and bone infarct. This swelling may be accompanied by warmth, redness, and fever (Bainbridge, Higgs, Maude, et al., 1985 ; Powars, 1975). Treatment is symptomatic and includes analgesics and hydration. Applications of local warmth by compresses, massage, or warm baths may provide relief. The parents should be encouraged to call the health care provider and have the child examined with the first occurrence of hand-and-foot syndrome. Thereafter, the parents should be encouraged to recognize the signs and symptoms and manage treatment on their own, provided the child is afebrile. Fever, as well as marked local findings of inflammation with exquisite tenderness, may hail the onset of osteomyelitis, characteristically caused by salmonella (Givner, Luddy, and Schwartz, 1981 ; Webb, and Serjeant, 1989). This is an infectious complication that can be a secondary event and always requires prompt medical attention. If osteomyelitis is suspected, the child should be seen as soon as possible. Appropriate evaluation may include bone aspiration, x-rays, bone and bone marrow scans, and bacterial culture (Kim, Alavi, Russell, et al., 1989).

## Health Maintenance

The health care provider must recognize that the infant with sickle cell disease also requires the well-child care which is standard pediatric practice.

For infants with sickle cell disease, the schedule of health maintenance visits need not differ substantially from that for well children. The important symptoms of illness-related events and their clinical signs should be stressed and pertinent additional information shared during all visits, with periodic repetition for emphasis. The importance of strict compliance with prophylactic penicillin should be repeated at each visit. The parent should plan visits every other month during the first year and, if all is well, quarterly visits during the second year of life. The schedule of immunizations recommended by the American Academy of Pediatrics, Centers for Disease Control, or the American Academy of Family Physicians should be followed, including the 1992 recommendation that every child receive hepatitis B vaccine, which is especially pertinent for sickle cell children, since they may require transfusion and therefore are at risk for hepatitis B (Ndumbe, and Nyouma, 1990). If measles is epidemic in the child's neighborhood, measles vaccine should be given at 6 months of age, since community-acquired infection is frequently followed by pneumonia.

Infants with sickle cell disease should be immunized against Haemophilus influenzae at the age of 2 months.

Although all the immunizations are important, immunizations for H. influenzae and Streptococcus pneumoniae are particularly crucial. H. influenzae is another cause of serious morbidity and mortality in the young child with sickle cell disease (Zarkowsky, Gallagher, Gill, et al., 1986). Both normal infants and those with sickle cell disease can be protected from H. influenzae infection by administration of the highly immunogenic protein conjugated H. influenzae vaccine (Gigliotti, Feldman, and Wang, 1991 ; Marcinak, Frank, Labotka, et al., 1991).

The child should also be given 23 valent pneumococcal vaccine as soon as possible after the second birthday with a booster 2 to 3 years later (Buchanan and Schiffman, 1980 ; Chudwin, Wara, and Mathay, 1983 ; Hales, and Barriere, 1979 ; Overturf, 1982). Since the efficacy of this vaccine is incomplete, penicillin prophylaxis must be continued. The need for prophylaxis beyond the age of 5 years is currently under study.

During routine visits, attention should be paid to all usual health maintenance issues. Children with sickle cell anemia have higher than average baseline metabolic rates (Enwonwu, 1988). Close attention must be given to the child's diet to make sure all necessary nutrients and adequate calories are supplied. Multivitamins for at least the first 2 years of life are appropriate.

Additional folic acid has not been shown to be necessary in all children (Pearson, and Cobb, 1964 ; Serjeant, 1985). Although the iron salvaged during hemolysis is not lost to the body, the child with sickle cell disease does require dietary iron for growth and can become iron-deficient. Iron studies can be performed and supplemental iron given, if indicated. In addition to the periodic assessment of complete blood count and reticulocyte counts mentioned above, occasional liver function tests and renal function tests will uncover early evidence of organ damage.

Throughout all clinical visits, home management skills must be stressed to the parents. Parents must be taught neither to overprotect nor neglect their affected child but to treat the child as normally as possible (Belgrave, and Molock, 1991). However, there are certain everyday precautions that can be taken by the caregiver to minimize vasoocclusive episodes. Any condition that tends to cause dehydration may precipitate sickling in the microvasculature. The child should always be given liberal access to fluids, and this is even more important when the weather is warm. The child should always be carefully shielded from cool temperatures, since cold may slow the circulation, causing stasis and the precipitation of vasoocclusive episodes. Immersion in cold water should be avoided as well as excessive exposure to cold ambient temperatures; the child must be dressed warmly in cold weather. The health care provider must be able to assist and refer for proper assistance with such crucial ancillary services as transportation for medical care; Women, Infant and Children (WIC) programs; and social and/or psychosocial services.