# Guideline: Laboratory Screening for Sickle Cell Disease

The laboratory must use a screening procedure that will detect sickle hemoglobin in the newborn. The laboratory has a responsibility to transmit the infant's results to the infant's health care provider and hospital of birth. Test results must be reported in understandable language that includes the identified phenotype, diagnostic possibilities, and sources where additional information may be obtained. The laboratory also should inform the infant's mother of the screening result, unless prohibited by law.

The laboratory is responsible for detecting conditions in which sickle hemoglobin is present. The primary goal is to screen for sickle cell disease, including its common forms: sickle cell anemia (Hb SS), sickle-hemoglobin C disease (Hb SC), S beta+-thalassemia (Hb S B+-thalassemia), and SB°-thalassemia (Hb S B°-thalassemia), as well as uncommon types such as Hb S-D Punjab, Hb S/O_Arab_, Hb S/Lepore, and Hb SE. Screening also will identify persons with sickle cell trait, hemoglobin C trait and disease, hemoglobin E trait, and Hb E disease.

Other laboratory responsibilities include accurate recordkeeping, the results reporting process, and quality assurance.

## Background

The principal hemoglobin in the newborn is fetal hemoglobin . Hb F is composed of two alpha (a) and two gamma (g) globins. During the last trimester, there is a progressive increase in B globin synthesis and a decrease in g-chain synthesis. In the normal-term infant, about 80 percent of the non-a globin is g-globin and 20 percent is globin. This accounts for the normal term infant having approximately 80 percent Hb F and 20 percent Hb A. Because the infant with sickle cell trait has both a normal B gene and a B^s^ gene, the infant will have a predominance of Hb F and both Hb A and Hb S. There always will be more Hb A than Hb S in these infants because a chains preferentially pair with normal B chains.

In normal infants, g-chain synthesis declines rapidly with a corresponding increase in B globins. By 1 year of age, the normal infant will have only 1 to 2 percent Hb F and 95+ percent Hb A. The remainder of the hemoglobin is Hb A_2_, composed of two a and two delta (d) globin chains.

Electrophoresis is the most commonly used first step to characterize hemoglobin. Cellulose acetate and isoelectric focusing (IEF) are the most commonly used electrophoretic methods. Electrophoresis separates different hemoglobins by electrical charge. Many but not all high performance liquid chromatography methods also separate hemoglobin by charge. Hemoglobin separation by citrate agar electrophoresis depends both on the charge of the hemoglobin and on the ability of the hemoglobin to combine with components in the agar gel mixture. (See Table 5 for a comparison of several testing methods.)

Table 5. Screening methods

Cellulose Acetate | Isoelectric Electrophoresis | High Performance Focusing | Liquid Chromatography
Equipment cost | $2,500 | $4,000 | $30,000
Cost per test (consumables) | $0.15-0.25 | $0.35-0.50 | $0.10-1.75
Samples run per hour | 200 | 72 | 5-20
Advantages | Semi-quantitative Simple to operate | Sharper bands | Automated Quantitative
Disadvantages | Densitometer for quantitation | Densitometer for quantitation | Complex to use

Note: Labor costs will vary with number of samples per run.

Table 6. Types of blood samples for hemoglobin screening tests

Cord Blood | Heel Stick | Heel Stick Heparinized Capillary | Filter Paper
Person obtaining specimen | RN or MD | RN or technician | RN or technician
Volume of sample | 3-5mL | 40µL | 10µL
Stability of sample | 2 weeks, 4°C | 1-2 weeks, 4°C | 1-2 weeks, 20°C
Equipment | Collection tube | Lancet Capillary tube | Lancet Filter paper
Cost per Specimen | $0.20 | $0.08 | $0.06
Advantages | Sharp bands on testing sample volume Other specimens may be collected at same time | Sharp bands on testing | Easy to ship Easy to label Other specimens may be collected at same time
Disadvantages | Shipping difficult Labeling difficult May break in transit | Shipping difficult Labeling difficult May break in transit | Blurred bands

Table 7. Sensitivity of laboratory methods for detecting hemoglobinopathy disease in newborns

Author and Year | Laboratory Methods | Number Screened | Number retested | Number true positives | Number false negatives | Sensitivity (percent) | Comments
Kramer, et al., 1979 | CA/AG | 3,976 | 138 | 26 [1] | 0 | 100 | Only sample of trait and AA retested
Galacteros, et al., 1980 | CA/AG | 835 | 835 | 3 [1] | 0 | 100
Pass, et al., 1986 | CA/AG | 3,942 | 2,433 | 59 [1] | 8 | 88 | AA not retested.
Gardner and Keitt, 1988 | CA/AG | 2,058 | 154 | 17 [2] | 0 | 100 | Estimates adjusted to account for only 47% of traits retested.
Griffiths, et al., 1988 | CA/AG | 40,445 | 156 | 21 [1] | 0 | 100 | AA not retested. Retrospective review of AS.
Githens, et al. 1990 | CA/AG | 526,711 | 1,694 | 74 [1] | 10 | 88 | AA not retested. 53% of traits retested.
Kinney, et al., 1989 | CA/AG | 10,783 | 115 | 20 [2] | 0 | 100 | Only a sample of AA and trait retested.
Lobel, et al., 1989 | CA/AG | 48,000 (approx) | ? | 79 | 4 | 95.2 | AA not retested.
Wethers (unpublished) | CA/AG | 10,000 | 8,500 | 16 [2] | 1 | 94.1 | Initial testing of cord blood followed by capillary specimen sent
Galacteros, et al., 1980 | IEF | 835 | 835 | 3 [1] | 0 | 100
McMahon (unpublished) | IEF | 1,754 | 1,754 | 11 | 0 | 100
Kleman and Lorey (unpublished) | HPLC/IEF | 1,182,202 | 4,663 | 553 [3] | 1 | 99.99 | Screening by HPLC and confirmation by IEF. AA not retested. Only 25% of trait retested.

* Sensitivity of pooled data using cellulose acetate followed by citrate agar: 93.1%.

Note: CA = cellulose acetate hemoglobin electrophoresis, alkaline pH; AG = agar gel hemoglobin electrophoresis, acid pH; IEF = isoelectric focusing; HPLC = high performance liquid chromatography. Result from testing of original specimen is confirmed by testing second specimen.

Table 8. Specificity of laboratory methods for detecting hemoglobinopathy disease in newborns

Author and Year | Laboratory Methods | Number Screened | Number retested | Number true positives | Number false negatives | Sensitivity (percent) | Comments
Kramer, et al., 1979 | CA/AG | 3,976 | 138 | 110 [1] | 0 | 100 | See Table 7
Galacteros, et al., 1980 | CA/AG | 835 | 835 | 833 [1] | 2 | 99.8
Gardner and Keitt, 1988 | CA/AG | 2,058 | 154 | 220 [2] | 4 | 98.2 | Estimates adjusted to account for only 47% of traits retested.
Kinney, et al., 1989 | CA/AG | 10,783 | 115 | 951 | 0 | 100 | Only a sample of AA and trait retested.
Wethers (unpublished) | CA/AG | 8,500 | 8,500 | 8,484 [1] | 2 | 99.9 | See Table 7
Galacteros, et al., 1980 | IEF | 835 | 835 | 835 [1] | 0 | 100
McMahon (unpublished) | IEF | 1,754 | 1,754 | 11 | 0 | 100

* Sensitivity of pooled data using cellulose acetate followed by citrate agar: 99.9%.

Note: CA = cellulose acetate hemoglobin electrophoresis, alkaline pH; AG = agar gel hemoglobin electrophoresis, acid pH; IEF = isoelectric focusing; HPLC = high performance liquid chromatography. Result from testing of original specimen is confirmed by testing second specimen.

Table 9. Results of repeated testing of same newborn specimen

Author and Year | Cellulose Acetate Disease | | Citrate Agar Disease | | Cellulose Acetate Followed Citrate Agar Disease | | Isoelectric Focusing Disease | | Column Chromatography [1] Disease
Author and Year | Yes | No | Yes | No | Yes | No | Yes | No | Yes | No
Galacteros, et al., 1980 | 5 | 783[2] | 5 | 783[2] | 3 | 785 [2]
Schedlbauer and Pass, 1989 | 3 | 3,270 | 3 | 3,270[3]
Hicks and Hughes, 1975 | 26 | 483 | 27 | 483
Jacobs, et al., 1986 | 11 | 81[2] | 11 | 81 [2] | 11 | 81
Schmidt, et al., 1976 | 3 | 831[2] | 3 | 831 [2]
Schroeder, et al., 1975 | | | | | | | | | 1 | 185

Hemoglobins with similar charges have similar migration patterns during electrophoresis. Many more hemoglobins have similar motility on cellulose acetate. For example, hemoglobins D and G have migration patterns similar to hemoglobin S; Hb E and Hb O_Arab_ migrate similar to Hb C.^ [2] ^ Hb F migrates between Hb A and Hb S on cellulose acetate at alkaline pH. In the newborn who has a large amount of Hb F, care must be taken to detect small amounts of Hb A and Hb S reliably.

[2] Common abnormal hemoglobins with similar electrophoretic mobility: Hb S, D, and G have similar electrophoretic mobility on cellulose acetate electrophoresis. Hemoglobin S is separable from hemoglobins D and G by agar electrophoreses; IEF and HPLC methods can distinguish dome D and G variants from Hb S. Hb C, E, and O have similar electrophoretic mobility on cellulose acetate electrophoresis. Hb C differs markedly from E and O on agar electrophoresis. Note: Letter designations refer only to electrophoretic mobility. In general, there is more than one abnormal hemoglobin with the same letter designation (for example, G_San Jose_ and G_Philadelphia_; O_Arab_ and O_Indonesia_).

Citrate agar electrophoresis is particularly useful because it separates clearly Hb F, A, S, and C. Agar electrophoresis distinguishes Hb S from G or D, and Hb C from E or O. Agar electrophoresis is rarely used as the primary electrophoretic method for screening, but it is used by many laboratories to confirm the presence of abnormal hemoglobins found by another technique. This practice of employing two laboratory methods is called a two-tier screening technique.

There are two tests for detection of Hb S that should not be used for newborn screening. These tests are: (1) the sickle cell preparation using sodium metabisulfite and (2) a solubility test using a concentrated phosphate buffer, a hemolyzing agent, and sodium dithionate. Both depend on the concentration of Hb S in the red cell or hemolysate. The low level of S hemoglobin in cells of the neonate is believed to explain the unreliability of these tests during the newborn period (Huntsman, Metters, and Yawson, 1972). These two methods should not be used for newborn screening or to confirm the presence of Hb S in the newborn.

## Reporting

The newborn sickle cell screening system is responsible for ensuring that the report of an infant identified as possibly having sickle cell disease is sent to the provider responsible for medical followup. The report must clearly indicate the likelihood that the infant may have sickle cell disease and stress the urgency for immediate followup.

Samples that show FS or FSC patterns should be reported as probable sickle cell anemia or probable hemoglobin SC disease, respectively. Samples containing more hemoglobin S than A (FSA pattern) should be reported as probably S B+-thalassemia. FC patterns should be reported as probable hemoglobin CC disease or C B°-thalassemia. FCA patterns should be reported as probable hemoglobin C B+-thalassemia. Traits (AS, AC, AE, FAS, FAC, FAE, etc.) should be reported as such. Table 10 lists the common phenotypes associated with hemoglobin disorders and their possible genotypes.

Table 10. Hemoglobin patterns

Screening Phenotype [1] | Possible Genotype | Parents [2] | Clinical Significance
FS | SS | AS x AS | Usually serious
FS | S Beta°-thalassemia | AS x ATH° | Usually serious
FS | S/HPFH | AS x A/HPFH | None
FSA | S Beta± thalassemia | AS x ATH+ | Variable
FSC | SC | AS x AC | Variable

Distinguishing between sickle trait and sickle B+-thalassemia relies on estimating the relative proportions of hemoglobins A and S, as there is always more Hb A than Hb S in persons with sickle cell trait. Since these proportions can be difficult to estimate, great caution must be used. If a question exists, it is advisable to report the sample as probable S B+-thalassemia.

At a minimum, reports from the laboratory should be sent to the hospital of birth, the health care provider responsible for the child (if one has been identified), and the administrative office of the survey program. Health care providers should be notified of patients with clinically significant disease by certified mail to stress the importance of immediate action (Broghamer Jr, Lockwood, and Keeling, 1981). Records must be kept and assessed regularly to assure that all infants identified with possible disease are located and provided with followup that includes confirmation of the screening result and assignment of a definitive diagnosis. Since followup may be difficult (Miller, Stilerman, Rao, et al., 1990), lines of responsibility must be clearly drawn.

Whether the infant's parents should be notified directly depends largely on local circumstances or law. Sending such a report assures that the parents are informed, but if prior education about screening was inadequate or absent, unnecessary anxiety may be created by the report. Reports to parents should be delivered by mail. In those instances where disease is suspected, a telephone call to parents may be used. There are advantages to making the call either before or after the estimated arrival of the letter. The person making the telephone call must be specially trained.

Reports to providers and/or parents should include a preliminary interpretation of the hemoglobin phenotype and stress the need for immediate medical followup. The reports should indicate where additional information can be obtained or list State, community, and other agencies that can provide such information. Followup and definitive diagnosis of infants suspected of having disease, however, is the responsibility of the infant's physician. Definitive diagnosis requires repeat testing to confirm the initial hemoglobin phenotype and additional studies to assign a probable (or definitive) genotype. Either venous or capillary blood can be used, but the larger sample obtained from venipuncture is recommended. Tables 11 and 12 compare various methods for sample collection and testing.

Table 11. Comparison of sample types for confirmation tests of hemoglobin screening

Venous Blood | Capillary Blood | (Heparinized Tubes)
Volume of sample | 2-5mL | 120-160µL (3-4 tubes)
Stability of sample | 2 weeks, 4°C | 1 - 2 weeks, 4°C
Equipment | Needle, Syringe, Tube | Lancet Tubes
Cost per specimen | $0.20 | $0.09 - $0.12
Advantages | Similar to screening tests
Disadvantages | Similar to screening tests

Table 12. Comparison of testing methods for confirmation tests

| Citrate Agar | Immunologic Electrophoresis | DNA Analysis Testing
Equipment cost | Can use same equipment as for cellulose acetate electrophoresis | None for commercial kit. | Polymerase chain reactor $10,000.
Cost per specimen | $1-$1.50 (for commercial plates; negligible for homemade plates). | $3.50-$3.75 | $5-$100
Advantages | Objective endpoint. Distinguishes S and C from G, D, E, O. | Easy to perform diagnosis from first sample if enough probes are used. | Definitive.
Disadvantages | Mobility of bands depends on concentration. Some extra bands. Not all lots of agar are satisfactory. | Commercial kits only test for Hb A and S. | Separate probe needed for each mutation.

Definitive diagnosis should be established by a two-tier testing routine, immunoassays, or DNA analysis. Additional tests must include examination of the infant's blood smear and measurement of the infant's hemoglobin concentration and red cell indices. When both parents are available for testing and agree to be tested, characterization of the parents' hemoglobin phenotype and their levels of Hb A2 and Hb F can facilitate a definitive diagnosis for the infant. When one or both parents are unavailable for study, analysis of the infant's B globin gene complex by DNA/RNA methods may yield a definitive diagnosis.

The parent should be given an identification card bearing the child's definitive diagnosis, the facility that made the diagnosis, and sufficient information to permit rechecking of the laboratory records at a later date. Results of all confirmatory tests should be reported to the administrative office of the screening program to ensure that program objectives are met. As a component of laboratory quality assurance, it is essential that confirmatory test results be reported to the screening laboratory.

The procedures for establishing a definitive diagnosis must be comprehensive enough to include not only infants with sickle cell disease, but also those who may have other hemoglobin disorders (Hb CC, Hb EE, or E B-thalassemia) and those with other less common hemoglobin variants.

## Quality Assurance and Quality Control

The laboratory must participate in a proficiency testing program and, when feasible, should retest at least a sample of all newborns screened to determine the sensitivity and specificity of its screening methodology.

There are multiple sources of error in screening for sickle cell disease. These include:

- Sampling errors, including incorrect labeling of sample, contamination of sample with maternal blood or transfusion, and improper collection.
- Transportation errors, including delays and exposure to high temperature.
- Testing errors, including poor technique, improper methods, or incorrect interpretation.
- Reporting errors secondary to patient misidentification or clerical errors.
- Errors in retesting, similar to the above.

All testing must be done by laboratories licensed by their respective States and must meet the requirements of the Clinical Laboratory Improvement Act of 1988 (CLIA 88). As part of the CLIA requirements, laboratories must meet standards for quality control and must participate in an extramural proficiency testing program (Therrell, Panny, Davidson, et al., 1990). Such a program (ISQAL) for neonatal hemoglobinopathy testing has been established recently by the Centers for Disease Control. Of 37 States that participated, only 21 performed a two-tier test (Adam, and Bell, 1992). Of the 36 laboratories that participated in the study, 35 (97%) recognized that a sample from a carrier of hemoglobin D did not contain hemoglobin S; but 2 of 36 laboratories misdiagnosed a sample from an infant with sickle cell anemia. Filter paper samples that had been in transit for 3 to 10 days showed the same percentages of hemoglobins F, A, D, C, and S as they had contained initially, confirming earlier reports of filter paper sample stability for this length of time.

Results of followup testing must be considered a part of the proficiency testing process and be included with the results of other proficiency tests. Based on the evidence presented, it is suggested that both false-positive and false-negative reports should each be less than 0.01 percent of total samples.

The sensitivity and specificity of laboratory methods that detect sickle cell trait, other trait conditions, and the normal hemoglobin phenotype have not been defined for newborns because no studies have been done where infants with these conditions were retested at a later date. As part of the laboratory's quality assurance program, consideration should be given to developing a plan where statistically valid random samples from infants with all phenotypes would be retested to establish rates of sensitivity and specificity for the testing methods. The infants could be located through well-baby clinics. Careful explanations to the parents would be a requirement for such a program. While the cost of this type of program may be prohibitive, it would be desirable to ensure the accuracy of the screening methodology.

The evidence presented in this section suggests that cellulose acetate followed by citrate agar hemoglobin electrophoresis, isoelectric focusing, or high performance liquid chromatography are acceptable laboratory methods for screening newborns. The selection of a specific method should be based upon the personnel and financial resources available to the laboratory. The laboratory must function as a component of a comprehensive newborn screening program.