# Guideline: Population To Be Screened

## Introduction

One of the panel's primary objectives was to determine the prevalence of sickle cell disease in different racial and ethnic newborn populations. Other objectives included determining the prevalence of other hemoglobinopathies that might be detected during screening. These data can be used to estimate the total cost and benefit of screening programs. Issues for future research are discussed at the end of this chapter.

All newborns should be screened for sickle cell disease by accurate laboratory techniques. The purpose of such screening is to reduce morbidity and mortality from sickle cell disease. Screening also can identify infants with sickle cell trait, as well as homozygotes and heterozygotes for other hemoglobin variants. Screening of populations with a low prevalence of Hb S is cost-effective when the screening is integrated into a laboratory that is also testing samples from a population with a high prevalence of Hb S.

This recommendation is based on the following analysis of various racial and ethnic populations and the reduction of morbidity and mortality from sickle cell disease by early identification, when coupled with comprehensive medical care and utilization of penicillin prophylaxis.

## Importance of Population Characteristics

To evaluate the effectiveness of a screening program, several factors must be assessed (Frame, 1986). These include the incidence (or in the case of genetic abnormalities, prevalence) of the condition to be identified by the screening test. Sickle cell disease is more prevalent in some racial groups than in others. If prevalence differs between identifiable subgroups within the population, then it must be determined if the most cost-effective approach is to screen the entire population or only specific subpopulations.

## Difficulties in Assessing Characteristics

Although many studies on the prevalence of sickle cell disease have been published, it is difficult to define accurately the probability that a specific newborn will have this condition. The U.S. population is very heterogeneous and is constantly changing, making it difficult to define with certainty the race of a specific individual. Race cannot be assigned solely by phenotypical characteristics or surnames. Similarly, race cannot be accurately defined by self-report or by the race of the parents, as these may differ. The lack of uniform standards for recordkeeping of racial or ethnic statistics may contribute to significant errors in the published reports of the prevalence of sickle cell disease in specific racial or ethnic groups.

## Assumptions

Because of these difficulties, the guideline makes several assumptions.

1. The same method of assessing race and ethnicity that was used in the studies cited below will be used in the future to implement the guideline if such identification is required.
2. Data in the cited studies represent the U.S. population as a whole, and the studies represent independent samples from that population.
3. There often is significant heterogeneity within an ethnic group. For example, Hispanics (or those with Hispanic surnames), include European Spaniards, as well as persons from the Caribbean Islands, Mexico, and Central and South America. This guideline utilizes the Census Bureau's methods for defining specific ethnic groups.

## Methods

A panel subcommittee was formed to develop prevalence estimates. The data used for the prevalence estimates cited in this guideline were derived primarily from a literature search described elsewhere in this guideline. The search produced 1,111 references dealing with population characteristics. After multiple reviews of the title and abstract lists, citations were selected for retrieval and data extraction. Articles were reviewed several times, and data were extracted using a standardized format. The panel's methodologist and subcommittee chair reviewed each article and the extracted data for completeness and accuracy. Twenty-two citations were used in this analysis.

Articles with data on the prevalence of hemoglobinopathies in U.S. population groups were categorized as follows.

- Group 1 -- Articles with data on the prevalence of hemoglobinopathies among specific ethnic groups.
- Group 2 -- Articles with data by geographic area and information about the ethnic/racial population studied but without prevalence data on specific ethnic/racial groups.
- Group 3 -- Articles with data by geographic area alone, with no ethnic or racial data.

Articles that had no data, only had data about non-U.S. populations, or were judged by the reviewers to have serious flaws in methodology were not included. Following categorization, Group I contained 11 articles (Broghamer Jr, Lockwood, and Keeling 1981 ; Carr, and Chapatwala, 1988 ; Diaz-Barrios, 1989 ; Gardner, and Keitt, 1988 ; Grover, Wethers, Shahidi, et al., 1978 ; Huisman, Harris, Stewart, et al., 1991 ; Mack, 1989 ; Meany, and Riggle, 1992 ; Pass, Gauvreau, Schedlbauer, et al., 1986 ; Powars, 1989 ; Ralston, Kmetz, Keeling, et al., 1981 ; Therrell, Simmank, and Wilborn, 1989) and data from the Council of Regional Networks for Genetic Services . Three articles were included in Group II (Anyane-Yeboa, 1989 ; Harris, and Eckman, 1989 ; Vichinsky, Hurst, Earles, et al., 1988). Seven articles (Barnes, Komarmy, and Novack, 1972 ; Castro, Winter, Lee, et al., 1981 ; Foster, Forbes, Hayes, et al., 1981 ; Lobel, Cameron, Johnson, et al., 1989 ; Pearson, 1989 ; Schedlbauer, and Pass, 1989 ; Wethers and Grover, 1986) and additional data from CORN (not broken down by ethnic group) were included in Group III. Only Group I data were used to estimate prevalences.

Data from the articles in each group were collected in separate data bases on IBM compatible microcomputers; dBase IV software was used to build, maintain, and query these three data bases. The software was also used to compute prevalence rates at birth in those cases where the published data only contained raw numbers.

Data were displayed in the form of printed tables for review by the subcommittee. Data in two classes were eliminated from further consideration: (1) data that were clearly incomplete (that is, indicated prevalence rates of trait that were near or below disease rates, or indicated disease rates that were at least an order of magnitude higher than otherwise indicated for the population studied) and (2) data that were superseded by newer, more complete data from the same or a related source.

In some cases, the subcommittee contacted authors to determine whether additional data were available to fill in missing data in the published literature. Additional unpublished data were received from Dr. Astrid Mack 1 to supplement the published data on Florida prevalences.

1 Mack, A., University of Miami, personal communication, 1991.

A key source of data was the CORN 1990 Newborn Screening Report (Meany and Riggle, 1992), which contained data from many State screening programs. The CORN data represent the most recently published data but do not include a separate category for Hispanics. These data were combined separately from the other literature as well as with the rest of the literature.

The data were analyzed with Bayesian meta-analysis, using the FAST*PRO program (Eddy, and Hasselblad, 1992) (with Jeffrey's noninformative priors). Meta-analysis was used to help estimate the prevalence of sickling diseases for each ethnic and/or racial group for which data were available.

## Results

The Bayesian meta-analysis was performed initially to determine the prevalence of sickle cell disease in the various racial and/or ethnic groups. This analysis is based on evidence shown in the evidence tables in the Guideline Report (Sickle Cell Disease Guideline Panel, in press). Meta-analysis was used to compute the rates with the assumption that Hb SS, Hb SC, and Hb S/B-thalassemia were the hemoglobin phenotypes to be found. The results given in Table 1 show the prevalences of these three phenotypes for each ethnic group. In the second column is the mean value of the prevalence; the third column shows the 95 percent confidence interval. Hispanics were separated into two groups: the first group included Hispanics from the Eastern States, where the population is primarily from the Caribbean Islands. The second group of Hispanics included those from the Western States where the Hispanic population is primarily Mexican-American. There are no usable CORN data for Hispanics and Native Americans. Table 1

Table 1. Prevalence per 100,000 population of sickle cell disease (Hb SS, Hb SC, Hb S/ [beta]-thalassemia) by race and/or ethnic group

Race and/or ethnic group | Mean prevalence | 95% confidence interval
White | 1.72 | 1.06 - 2.66
White | 1.90 | 1.09 - 3.10
Black | 289.00 | 277 - 300
Black | 274.00 | 250 - 300
Hispanic, total | 5.28 | 2.60 - 9.61
Hispanic, Eastern States | 89.80 | 27.0 - 190
Hispanic, Western States | 3.14 | 1.19 - 6.86
Asian | 7.61 | 1.85 - 57.2
Asian | 8.75 | 2.11 - 1.99
Native Americans | 36.20 | 0.0351 - 182

A second meta-analysis was performed to determine the prevalence of sickle cell trait (Table 2). Only the AS phenotype was included in this analysis. The subcommittee also analyzed other disease states, including children who were homozygous or doubly heterozygous for other abnormal hemoglobins, as shown in Table 3. Finally, a meta-analysis of hemoglobinopathy traits other than S was performed as shown in Table 4. Because some articles did not indicate the frequencies of non-sickle hemoglobinopathies and trait conditions, the numbers are probably low. When articles did not indicate the hemoglobin phenotype of the other category, it was classified as other trait for this analysis.

Table 2. Prevalence per 100,000 population of sickle cell trait (AS) by race and/or ethnic group

Race and/or Ethnic Group Interval | Mean prevalence | 95% confidence
White | 242 | 234-251
White | 258 | 247-267
Black | 7000 | 6910-7090
Black | 6550 | 6530-6770
Hispanic, total | 579 | 545-615
Hispanic, Eastern States | 3040 | 2590-3550
Hispanic, Western States | 508 | 476-543
Asian | 133 | 103-169
Asian | 106 | 77.6-142
Native Americans | 181 | 30.1-464

Table 3. Prevalence per 100,000 population of doubly heterozygous or homozygous hemoglobinopathies other than SS, SC, or S beta-thalassemia by race and/or ethnic group

Race and/or Ethnic Group Interval | Mean prevalence | 95% confidence
White | 5.550 | 4.62-7.10
White | 0.853 | 0.355-1.75
Black | 35.300 | 28.6-43.1
Black | 33.200 | 25.4-42.7
Hispanic, total | 12.2 | 7.75-18.2
Asian | 235.000 | 194-282

Table 4. Prevalence per 100,000 population of other hemoglobinopathy traits by race and/or ethnic group

Race and/or Ethnic Group Interval | Mean prevalence | 95% confidence
White | 223 | 215-2320
White | 241 | 230-252
Black | 332 | 325-339
Black | 368 | 359-377
Hispanic, total | 189 | 169-210
Asian | 323 | 307-339

## Discussion

The data presented in this section of the guideline are from sickle cell screening programs. Although the results were obtained by different screening methods, the results are remarkably consistent for most races and ethnic groups. The data, however, show a marked difference between Hispanics from the Eastern United States (primarily Caribbean or Latin American origin) and those who live in the Western States (primarily of Mexican origin). Data for the Western States are from Texas and California; data for the Eastern States are from Florida and New York. Our analysis of these data revealed that Hispanics from the Eastern States have sickle cell disease rates approaching rates in the black population, while Hispanics from the Western States have lower rates, approximating those in the white population. This difference is not apparent when Hispanics are viewed as a single group.

Although no cases of sickle cell disease were encountered in Native Americans, the data for Native Americans are too sparse to yield conclusions about the prevalence of sickle cell disease in this group. The data also do not permit assessment of the prevalence of sickle cell disease among different Asian groups.

The data listed for other traits (Table 4) and children doubly heterozygous or homozygous for conditions other than Hb AA, Hb SS, Hb SC, or Hb S B-thalassemia (Table 3) should be viewed with considerable skepticism. Recordkeeping was erratic, and in most cases, it was not clear whether unusual hemoglobins were included. In some cases, the phenotype was listed only as other, which did not permit distinction between traits and disease conditions; trait was assumed in those cases. In addition, several studies showed anomalous rates of other traits and conditions, with the homozygous or doubly heterozygous exceeding the number of traits. The CORN data do not match with all the data for whites in Table 3, indicating these data are questionable and may be biased due to the grouping of Hispanics with whites.

The CORN data demonstrate different prevalences of sickle cell disease among the black populations in different States. Figure 1 shows the density function for sickle cell for each State and the effect of using meta-analysis to combine these results. Louisiana and California (curves for these States peak on the left side of the figure) show lower prevalences of sickle cell than Texas, Virginia, and Michigan (curves peak on the right). Wisconsin (the broader peak on the left) lies in the middle. The dotted line represents the results of the meta-analytic combination of the other lines. The reason for these differences is not known, but they may stem from a difference in the admixture between racial and ethnic groups in these areas. It should be emphasized that the selection of racial and ethnic categories for use in this analysis does not imply that any of these groups are pure or even consistently identified. For example, our analysis shows a higher prevalence of sickle cell disease among whites than the analysis by Tsevat and colleagues (1991) . This is likely due to the inexact determination (or even definition) of white. However, to the extent that the methods used to determine race or ethnicity in our analysis are the same as those used in a future study, the same results should be obtained.

Meta-analysis of CORN data on prevalence of sickle cell disease among black populations

Although there are significant reasons to believe that the populations studied do differ by location, the use of the hierarchic approach biased the results into higher prevalences. This occurred because many of the samples were of small to moderate size and had zero occurrences. When a large study with a low prevalence is combined with a small study with zero prevalence, the hierarchic approach yields a prevalence estimate that is higher than the prevalence of the large study. As a result, it was felt that straight Bayesian meta-analysis would yield a more accurate estimate of the mean. However, the use of Bayesian meta-analysis resulted in unreasonably tight confidence intervals that are difficult to believe. There is greater (but not measured) uncertainty about the estimates than indicated by the confidence intervals.

## Cost-Effectiveness of Screening

The cost-effectiveness of universal neonatal hemoglobinopathy screening is a complicated issue. Tsevat and colleagues (1991) found that the cost per life saved by universal screening would vary greatly among those populations with mixed racial composition. They equated the cost-effectiveness of universal screening solely with the prevention of death from pneumococcal sepsis by the administration of prophylactic penicillin to infants whose sickle cell disease would otherwise have been unrecognized prior to age 3 years. Their adaptation of risk-reduction data from the Prophylactic Penicillin Study (PROPS), however, biased their results against a policy of early diagnosis (Gaston, Verter, Woods, et al., 1986). All patients in PROPS were known to have sickle cell disease prior to entry, and all were followed carefully; almost two-thirds of the patients were older than 12 months when enrolled. Further, the theoretical population on which Tsevat's most striking result was based does not correspond to any existing U.S. screening jurisdiction.

Lane and colleagues (1992), using a computerized decision model to analyze their experience in Colorado, found that easily overlooked procedural and administrative costs associated with targeted screening could be high enough to make universal screening less expensive. Hidden costs included loss of economy of scale in the screening laboratory and additional personnel costs for determining each infant's ethnic background.

Sprinkle, Hynes, and Konrad (in press) projected the costs of finding cases of sickle cell disease in 53 U.S. jurisdictions (the 50 States, the District of Columbia, Puerto Rico, and the Virgin Islands) through universal neonatal hemoglobinopathy screening. They compared these costs to the costs projected for finding cases of phenylketonuria (PKU) through the universal neonatal screening practices long established for PKU in the same jurisdictions. Their estimates suggested that 35 jurisdictions would be able to find a case of sickle cell disease for less, often far less, than one-half the cost of finding a case of PKU. The remaining 18 jurisdictions could substantially reduce the per-case costs, typically for finding both diseases, by combining efforts with other States. In fact, many States already have used this approach to reduce costs. States with relatively few African-Americans tended to be States with small populations in which the efficiency of screening for PKU and other metabolic diseases also could be enhanced by such combination, whether or not they decided to screen for hemoglobinopathies. States deciding to simplify the screening of neonates at high risk for sickle cell disease by testing all neonates, regardless of racial classification, would have little trouble finding demographically complementary screening partners with which to form low-cost screening composites.

## Issues for Future Research

Although more than 40 States now screen for sickle cell disease, the number of States reporting usable data to CORN remains low. Much of the reported data are inconsistent or incomplete and could not be used in this analysis. Since the data reported here are not correlated with the type of screening program (universal vs. targeted), there is still some room for error. Improved and, more importantly, uniform methods for identifying and classifying subsets of the population are needed. Population subsets other than the general categories of blacks and whites still lack sufficient size to yield meaningful results. The prevalence among Hispanics, when analyzed by geographic area, reflects differences that should be substantiated with further data. In addition, researchers should investigate possible differences among Asians. An additional analysis of the cost- effectiveness of sickle cell screening for low-risk populations should be undertaken. This analysis should use actual prevalence data and include the benefits of early detection of sickle cell disease beyond the life-saving effects of penicillin prophylaxis.