# Availability of Guidelines

For each clinical practice guideline developed under the sponsorship of the Agency for Health Care Policy and Research (AHCPR), several versions are produced to meet different needs.

The Guideline Report contains the Clinical Practice Guideline with complete supporting materials, including background information, methodology, literature review, scientific evidence tables, and a comprehensive bibliography.

The Clinical Practice Guideline and the Quick Reference Guide for Clinicians are companion documents for use as desktop references for clinical decisionmaking in the day-to-day care of patients. Recommendations, algorithms or flow charts, tables and figures, and pertinent references are included.

A Patient's Guide, available in English and Spanish, is an informational booklet for the general public to increase consumer knowledge and involvement in health care decisionmaking.

Guideline information also will be available for on-line retrieval through the National Library of Medicine, the National Technical Information Service, and some computer-based information systems of professional associations, nonprofit organizations, and commercial enterprises.

To order guideline products or to obtain further information on their availability, call the AHCPR Clearinghouse toll-free at 800-358-9295, or write to: AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907.