# Acronyms

- AHCPR
- Agency for Health Care Policy and Research
- BDI
- Beck Depression Inventory
- BMT
- Behavioral marital therapy
- CGI
- Clinical Global Impression
- CPM
- Confidence profile method
- ECT
- Electroconvulsive therapy
- FDA
- Food and Drug Administration
- GAD
- Generalized anxiety disorder
- HAM-D
- Hamilton Rating Scale for Depression
- MAOI
- Monoamine oxidase inhibitor
- NIMH
- National Institute of Mental Health
- SSRI
- Selective serotonin reuptake inhibitor
- TCA
- Tricyclic antidepressant