# References

Abou-Saleh MT, Coppen A. Classification of depression and response to antidepressant therapies. Br J Psychiatry 1983;143:601-3.
Akiskal HS. A proposed clinical approach to chronic and "resistant" depressions: evaluation and treatment. J Clin Psychiatry 1985;46:32-6.
Altamura AC, Mauri M. Plasma concentrations, information and therapy adherence during long-term treatment with antidepressants. Br J Clin Pharmacol 1985;20(6):714-6.
American Medical Association. Drug evaluations. Chicago: AMA; 1990.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. rev. Washington, DC: American Psychiatric Press; 1987.
Amsterdam J, Brunswick DJ, Mendels J. High dose desipramine, plasma drug levels and clinical response. J Clin Psychiatry 1979;40(3):141-3.
Amsterdam J, Brunswick DJ, Mendels J. The clinical application of tricyclic antidepressant pharmacokinetics and plasma levels. Am J Psychiatry 1980;137:653-62.
Anderson CM, Griffin S, Rossi A, Pagonis I, Holder DP, Treiber R. A comparative study of the impact of education vs. process groups for families of patients with affective disorders. Fam Process 1986;25(2):185-205.
Anton RF, Burch EA. Amoxapine versus amitriptyline combined with perphenazine in the treatment of psychotic depression. Am J Psychiatry 1990;147(9):1203-8.
Anton RF, Sexauer JD. Efficacy of amoxapine in psychotic depression. Am J Psychiatry 1983;140(10):1344-7.
Appelbaum PS, Russell GV, Orsulak PJ, Schildkraut JJ. Clinical utility of tricyclic antidepressant blood levels: a case report. Am J Psychiatry 1979;136:339-41.
Avery D, Lubrano A. Depression treated with imipramine and ECT: the DeCarolis study reconsidered. Am J Psychiatry 1979;136:559-62.
Avery D, Winokur G. The efficacy of electroconvulsive therapy and antidepressants in depression. Biol Psychiatry 1977;12(4):507-23.
Bandura A. Social learning theory. Englewood Cliffs, NJ: Prentice-Hall; 1977.
Baumann P. New aspects in research on blood levels and bioavailability of antidepressants. Psychopathology 1986;19 Suppl 2:79-84.
Beach SRH, Arias I, O'Leary KD. Risk for depression as a factor of social support. Paper presented at: Eastern Psychological Association; 1983; Philadelphia.
Beach SRH, Jouriles EN, O'Leary KD. Extramarital sex: impact on depression and commitment in couples seeking marital therapy. J Sex Marital Ther 1985;11:99-108.
Beasley CM, Sayler ME, Cunningham GE, Weiss AM, Masica DN. Fluoxetine in tricyclic refractory major depressive disorder. J Affect Disord 1990;20:193-200.
Beck AT, Hollon SD, Young JE, Bedrosian RC, Budenz D. Treatment of depression with cognitive therapy and amitriptyline. Arch Gen Psychiatry 1985;42:142-8.
Beck AT, Rush AJ, Shaw BF, Emery G. Cognitive therapy of depression. New York: Guilford Press; 1979.
Beck AT, Ward CH, Mendelson M, Mock J, Erbaugh J. An inventory for measuring depression. Arch Gen Psychiatry 1961;4:561-71.
Bellack AS, Hersen M, Himmelhoch JM. A comparison of social-skills training, pharmacotherapy and psychotherapy for depression. Behav Res Ther 1983;21(2):101-7.
Bialos D, Giller E, Jatlow P, Docherty J, Harkness L. Recurrence of depression after discontinuation of long-term amitriptyline treatment. Am J Psychiatry 1982;139(3):325-9.
Bielski RJ, Friedel RO. Prediction of tricyclic antidepressant response: a critical review. Arch Gen Psychiatry 1976;33:1479-89.
Blackburn IM, Bishop S. Changes in cognition with pharmacotherapy and cognitive therapy. Br J Psychiatry 1983;143:609-17.
Blackburn IM, Bishop S, Glen AIM, Whalley LJ, Christie JE. The efficacy of cognitive therapy in depression: a treatment trial using cognitive therapy and pharmacotherapy, each alone and in combination. Br J Psychiatry 1981;139:181-9.
Blackburn IM, Eunson KM, Bishop S. A two-year naturalistic follow-up of depressed patients treated with cognitive therapy, pharmacotherapy and a combination of both. J Affect Disord 1986;10:67-75.
Bothwell S, Weissman MM. Social impairments four years after an acute depressive episode. Am J Orthopsychiatry 1977;47:231-7.
Bourin MS, Kergueris MF, Lapierre YD. Therapeutic monitoring of treatment with antidepressants. Psychiat J Univ Ottawa 1989;14:460-2.
Bowers WA. Treatment of depressed in-patients: cognitive therapy plus medication, relaxation plus medication, and medication alone. Br J Psychiatry 1990;156:73-8.
Brandon S, Cowley P, McDonald C, Neville P, Palmer R, Wellstood-Eason S. Electroconvulsive therapy: results in depressive illness from the Leicestershire trial. Br Med J 1984;288(6410):22-5.
Brown GW, Harris T. Social origins of depressions: a study of psychiatric disorders in women. London: Tavistock Press; 1978.
Brown RA, Lewinsohn PM. A psychoeducational approach to the treatment of depression: comparison of group, individual, and minimal contact procedures. J Consult Clin Psychol 1984;52(5):774-83.
Brown RP, Frances A, Kocsis JH, Mann JJ. Psychotic vs non-psychotic depression: comparison of treatment response. J Nerv Ment Dis 1982;170(10):635-7.
Brown RP, Sweeney J, Frances A, Kocsis JH, Loutsche E. Age as a predictor of treatment response in endogenous depression. J Clin Psychopharmacol 1983; 3:176-8.
Carney RM, Rich MW, Freedland KE, Saini J, teVelde A, Simeone C, Clark K. Major depressive disorder predicts cardiac events in patients with coronary artery disease. Psychosom Med 1988;50:627-33.
Carney RM, Rich MW, teVelde A, Saini J, Clark K, Freedland KE, editors. The incidence, significance and detection of depression in patients with suspected coronary artery disease. Proceedings of NIMH Conference on Mental Disorders in General Health Care Settings; 1985 Jun 26-27; Seattle. 1987a. p. 37-9.
Carney RM, Rich MW, teVelde A, Saini J, Clark K, Jaffe AS. Major depressive disorder in coronary artery disease. Am J Cardiol 1987b;60:1273-5.
Chan CH, Janicak PG, Davis JM, Altman E, Andriukaitis S, Hedeker D. Response of psychotic and nonpsychotic depressed patients to tricyclic antidepressants. J Clin Psychiatry 1987;48:197-200.
Charney DS, Nelson JC. Delusional and nondelusional unipolar depression: further evidence for distinct subtypes. Am J Psychiatry 1981;138:328-33.
Charney DS, Price LH, Heninger GR. Desipramine-yohimbine combination treatment of refractory depression: implications for the beta-adrenergic receptor hypothesis of antidepressant action. Arch Gen Psychiatry 1986;43(12):1155-61.
Cohn JB, Wilcox C. A comparison of fluoxetine, imipramine, and placebo in patients with major depressive disorder. J Clin Psychiatry 1985;46(3 Pt 2):26-31.
Cole JO, Schatzberg AF, Sniffin C, Zolner J, Cole JP. Trazodone in treatment-resistant depression: an open study. J Clin Psychopharmacol 1981;1 Suppl:49-54.
Coppen A, Ghose K, Montgomery S, Rama Rao VA, Bailey J, Christiansen J, Mikkleson PL, van Praag HM, van de Poel F, Minsker EJ, Kozulja VG, Matussek N, Kungkunz G, Jorgensen A. Amitriptyline plasma-concentration and clinical effect: a World Health Organisation Collaborative Study. Lancet 1978;1(8055):63-6.
Coppen A, Mendelwicz J, Kielholz P. Pharmacotherapy of depressive disorders: a consensus statement. Geneva: World Health Organization; 1986.
Coppen A, Montgomery SA, Gupta RK, Bailey JE. A double-blind comparison of lithium carbonate and maprotiline in the prophylaxis of the affective disorders. Br J Psychiatry 1976;128:479-85.
Corne SJ, Hall JR. A double-blind comparative study of fluoxetine and dothiepin in the treatment of depression in general practice. Int Clin Psychopharmacol 1989;4(3):245-54.
Corney RH. Marital problems and treatment outcome in depressed women: a clinical trial of social work intervention. Br J Psychiatry 1987;151:652-9.
Covi L, Lipman RS. Cognitive behavioral group psychotherapy combined with imipramine in major depression. Psychopharmacol Bull 1987;23(1):173-6.
Cross design synthesis: a new strategy for medical effectiveness research. Washington, DC: US GAO; 1992. Report No. B244808.
Davidson JR, McLeod MN, Kurland AA, White HL. Antidepressant drug therapy in psychotic depression. Br J Psychiatry 1977;131:493-6.
Davidson J, McLeod M, Law-Yone B, Linnoila M. A comparison of electroconvulsive therapy and combined phenelzine-amitriptyline in refractory depression. Arch Gen Psychiatry 1978;35(5):639-42.
Davidson J, Pelton S. Forms of atypical depression and their response to antidepressant drugs. Psychiatry Res 1986;17:87-95.
de Jong R, Treiber R, Henrich G. Effectiveness of two psychological treatments for inpatients with severe and chronic depressions. Cognitive Ther Res 1986;10:645-63.
DeCarolis V, Gilberti F, Roccatagliata G, et al. Imipramine and electroshock in the treatment of depression: a clinical statistical analysis of 437 cases. Dis Nerv Syst 1964;25:29-42.
Depression Guideline Panel. Depression in primary care: detection, diagnosis, and treatment. Technical report. Number 5. Rockville, MD: US Department of Health and Human Services, Public Health Service; forthcoming.
DiMascio A, Klerman GL, Prusoff BA. Relative safety of amitriptyline in maintenance treatment of depression. Arch Gen Psychiatry 1975;160:34-41.
DiMascio A, Klerman GL, Weissman MM, Prusoff BA, Neu C, Moore P. A control group for psychotherapy research in acute depression: one solution to ethical and methodological issues. J Psychiatr Res 1979;15:189-97.
DiMascio A, Weissman MM, Prusoff BA, Neu C, Zwilling M, Klerman GL. Differential symptom reduction by drugs and psychotherapy in acute depression. Arch Gen Psychiatry 1979;36:1450-6.
Dinan TG, Barry S. A comparison of electroconvulsive therapy with a combined lithium and tricyclic combination among depressed tricyclic nonresponders. Acta Psychiatr Scand 1989;80:97-100.
Dobson KS. A meta-analysis of the efficacy of cognitive therapy for depression. J Consult Clin Psychol 1989;46(3):414-9.
Doogan DP, Caillard V. Sertraline in the prevention of depression. Br J Psychiatry 1992;160:217-22.
Dornseif BE, Dunlop SR, Potvin JH, Wernicke JF. Effect of dose escalation after low-dose fluoxetine therapy. Psychopharmacol Bull 1989;25(1):71-9.
Eddy DM, Hasselblad V, Schacter R. A Bayesian method for synthesizing evidence: the confidence profile method. Int J Technol Assess Health Care 1990;6:31-5.
Electroconvulsive therapy. Psychiatr Clin North Am 1991;14(4):793-1016.
Elkin I, Shea TM, Watkins JT, Imber SD, Sotsky SM, Collins JF, Glass DR, Pilkonis PA, Leber WR, Docherty JP, Fiester SJ, Parloff MB. National Institute of Mental Health Treatment of Depression Collaborative Research Program. General effectiveness of treatments. Arch Gen Psychiatry 1989;46:971-82.
Fabre LF Jr, Feighner JP. Long-term therapy for depression with trazodone. J Clin Psychiatry 1983;44(1):17-21.
Fairchild CJ, Rush AJ, Vasavada N, Giles DE, Khatami M. Which depressions respond to placebo? Psychiatry Res 1986;18(3):217-26.
Fawcett J, Scheftner W, Clark D, Hedeker D, Gibbons R, Coryell W. Clinical predictors of suicide in patients with major affective disorders: a controlled prospective study. Am J Psychiatry 1987;144:35-40.
Feet PO, Larsen S, Robak OH. A double blind study in out-patients with primary non-agitated depression treated with imipramine in combination with placebo, diazepam or dixyrazine. Acta Psychiatr Scand 1985;72(4):334-40.
Feighner JP. Trazodone in major affective disorders. Psychopathology 1984;17 Suppl 2:15-23.
Feighner JP, Brauzer B, Gelenberg AJ, Gomez E, Kiev A, Kurland ML, Weiss BL. A placebo-controlled multicenter trial of Limbitrol versus its components (amitriptyline and chlordiazepoxide) in the symptomatic treatment of depressive illness. Psychopharmacology 1979;61(2):217-25.
Feighner JP, Cohn JB. Double-blind comparative trials of fluoxetine and doxepin in geriatric patients with major depressive disorder. J Clin Psychiatry 1985;46(3):20-5.
Ferster CB. A functional analysis of depression. Am Psychol 1973;28(10):857-70.
Foley SH, Rounsaville BJ, Weissman MM, Sholomskas D, Chevron E. Individual vs. conjoint interpersonal psychotherapy for depressed patients with marital disputes. Paper presented at: Annual meeting of the American Psychiatric Association; 1987 May; Chicago.
Frances A, Brown RP, Kocsis JH, Mann JJ. Psychotic depression: a separate entity? Am J Psychiatry 1981;138:831-3.
Frank E, Kupfer DJ. Efficacy of combined imipramine and interpersonal psychotherapy. Psychopharmacol Bull 1987;23(1):4-7.
Frank E, Kupfer DJ. Axis II personality disorders and personality features in treatment-resistant and refractory depression. In: Roose SP, Glassman AH, editors. Treatment strategies for refractory depression. Washington, DC: American Psychiatric Press; 1990. p. 205-21.
Frank E, Kupfer DJ, Jacob M, Jarrett D. Personality features and response to acute treatment in recurrent depression. J Pers Disord 1987;1(1):14-26.
Frank E, Kupfer DJ, Perel JM, Cornes C, Jarrett DB, Mallinger AG, Thase ME, McEachran AB, Grochocinski VJ. Three-year outcomes for maintenance therapies in recurrent depression. Arch Gen Psychiatry 1990;47:1093-9.
Frank E, Prien RF, Jarrett JB, Keller MB, Kupfer DJ, Lavori P, Rush AJ, Weissman MM. Conceptualization and rationale for consensus definitions of terms in major depressive disorder: response, remission, recovery, relapse, and recurrence. Arch Gen Psychiatry 1991;48:851-5.
Freeman CPL, Basson JV, Creighton A. Double blind controlled trial of ECT and simulated ECT in depressive illness. Lancet 1978;1(8067):738-40.
Friedman AS. Interaction of drug therapy with marital therapy in depressed patients. Arch Gen Psychiatry 1975;32:619-37.
Gallagher DE, Thompson LW. Treatment of major depressive disorder in older adult outpatients with brief psychotherapies. Psychotherapy: theory, research, and practice 1982;19(4):482-90.
Gallagher DE, Thompson LW. Effectiveness of psychotherapy for both endogenous and nonendogenous depression in older adult outpatients. J Gerontol 1983;38(6):707-12.
Gallagher-Thompson D, Hanley-Peterson P, Thompson LW. Maintenance of gains versus relapse following brief psychotherapy for depression. J Consult Clin Psychol 1990;58(3):371-4.
Gangadhar BN, Kapur RL, Kalyanasundaram S. Comparison of electroconvulsive therapy with imipramine in endogenous depression: a double blind study. Br J Psychiatry 1982;141:367-71.
Georgotas A, McCue RE, Cooper TB. A placebo-controlled comparison of nortriptyline and phenelzine in maintenance therapy of elderly depressed patients. Arch Gen Psychiatry 1989;46:783-6.
Giles DE, Jarrett RB, Biggs MM, Guzick DS, Rush AJ. Clinical predictors of recurrence in depression. Am J Psychiatry 1989;146:764-7.
Giles DE, Jarrett RB, Roffwarg HP, Rush AJ. Reduced REM latency: a predictor of recurrence in depression. Neuropsychopharmacology 1987;1:33-9.
Giller E Jr, Bialos D, Harkness L, Jatlow P, Waldo M. Long-term amitriptyline in chronic depression. Hillside J Clin Psychiatry 1985;7(1):16-33.
Glassman AH, Kantor SJ, Shostak M. Depression, delusions, and drug response. Am J Psychiatry 1975;132(7):716-9.
Glassman AH, Schildkraut JJ, Orsulak PJ, et al. Tricyclic antidepressant blood level measurements and clinical outcome: an APA task force report. Am J Psychiatry 1985;142:155-62.
Glen AIM, Johnson AL, Shepherd M. Continuation therapy with lithium and amitriptyline in unipolar depressive illness: a randomized, double-blind, controlled trial. Psychol Med 1984;14(1):37-50.
Gonzales LR, Lewinsohn PM, Clarke GN. Longitudinal follow-up of unipolar depressives: an investigation of predictors of relapse. J Consult Clin Psychol 1985;53:461-9.
Goodwin FK, Jamison KR. Manic-depressive illness. New York: Oxford University Press; 1990.
Greenhouse JB, Stangl D, Kupfer DJ, Prien RF. Methodologic issues in maintenance therapy clinical trials. Arch Gen Psychiatry 1991;48(4):313-8.
Gregory S, Shawcross CR, Gill D. The Nottingham ECT study a double blind comparison of bilateral, unilateral and simulated ECT in depression. Br J Psychiatry 1985;146:520-4.
Guy W. ECDEU assessment manual for psychopharmacology. Washington, DC: US Department of Health, Education, and Welfare; 1976.
Hall RCW, Popkin MK, Devaul RA, Faillace LA, Stickney SK. Physical illness presenting as psychiatric disease. Arch Gen Psychiatry 1978;35:1315-20.
Hamilton M. A rating scale for depression. J Neurol Neurosurg Psychiatry 1960;23:56-62.
Hamilton M. Development of a rating scale for primary depressive illness. Br J Soc Clin Psychol 1968;6:278-96.
Hamilton M. The effect of treatment on the melancholias (depressions). Br J Psychiatry 1982;140:223-30.
Hersen M, Bellack AS, Himmelhoch JM, Thase ME. Effects of social skills training, amitriptyline, and psychotherapy in unipolar depressed women. Behav Ther 1984;15:21-40.
Hinchliffe M, Hooper D, Roberts FJ. The melancholy marriage. New York: Wiley; 1978.
Hogg JA, Deffenbacher JL. A comparison of cognitive and interpersonal-process group therapies in the treatment of depression among college students. J Couns Psychol 1988;35(3):304-10.
Hollon SD, DeRubeis RJ, Seligman MEP. Cognitive therapy and the prevention of depression. Appl Prev Psychology 1992;1:89-95.
Hollon SD, Shelton RC, Loosen PT. Cognitive therapy in relation to pharmacotherapy for depression. J Consult Clin Psychol 1991;59:88-99.
Hooley JM, Orley J, Teasdale JD. Levels of expressed emotion and relapse in depressed outpatients. Br J Psychiatry 1986;148:642-7.
Hough RL, Landsverk JA, Karno M, Burnam MA, Timbers DM, Escobar JI, Regier DA. Utilization of health and mental health services by Los Angeles Mexican Americans and non-Hispanic whites. Arch Gen Psychiatry 1987;44:702-9.
Howarth BG, Grace MGA. Depression, drugs, and delusions. Arch Gen Psychiatry 1985;42:1145-7.
Jacobson NS, Holtzworth-Munroe A, Schmaling KB. Marital therapy and spouse involvement in the treatment of depression, agoraphobia, and alcoholism. J Consult Clin Psychol 1989;57(1):5-10.
Jacobson NS, Schmaling KB, Salusky S, Follette V, Dobson K. Marital therapy as an adjunct treatment for depression. Paper presented at: Annual meeting of the Association for the Advancement of Behavior Therapy; 1987 Nov; Boston.
Jarrett RB, Ramanan J, Eaves GG, Kobes R, Basco MR, Rush AJ. How prophylactic is cognitive therapy in treating depressed outpatients? Paper presented at: The World Congress of Cognitive Therapy; 1992 Jun; Toronto, Canada.
Johnson J, Weissman MM, Klerman GL. Service utilization and social morbidity associated with depressive symptoms in the community. JAMA 1992;267:1478-83.
Johnstone EC, Lawler P, Stevens M, Deakin JFW, Frith CD, McPherson K, Crow TJ. The Northwick Park Electroconvulsive Therapy Trial. Lancet 1980;2:1317-20.
Kane JM, Quitkin FM, Rifkin A, Ramos-Lorenzi JR, Nayak DD, Howard A. Lithium carbonate and imipramine in the prophylaxis of unipolar and bipolar II illness: a prospective, placebo-controlled comparison. Arch Gen Psychiatry 1982;39(9):1065-9.
Kaskey GB, Nasr S, Meltzer HY. Drug treatment in delusional depression. Psychiatry Res 1980;2(3):267-77.
Kathol RG, Wenzel RP. Natural history of symptoms of depression and anxiety during inpatient treatment on general medicine wards. J Gen Intern Med 1992;7:287-93.
Keitner GI, Ryan CE, Miller LW, Kohn R, Epstein NB. 12-month outcome of patients with major depression and comorbid psychiatric or medical illness (compound depression). Am J Psychiatry 1991;148:345-50.
Klerman GL, DiMascio A, Weissman MM, Prusoff B, Paykel ES. Treatment of depression by drugs and psychotherapy. Am J Psychiatry 1974;131(2):186-92.
Klerman GL, Weissman MM. Interpersonal psychotherapy (IPT) and drugs in the treatment of depression. Pharmacopsychiatry 1987;20:3-7.
Klerman GL, Weissman MM, Rounsaville BJ, Chevron RS. Interpersonal psychotherapy of depression. New York: Basic Books; 1984.
Kornblith SJ, Rehm LP, O'Hara MW, Lamparski DM. The contribution of self-reinforcement training and behavioral assignments to the efficacy of self-control therapy for depression. Cognitive Ther Res 1983;7(6):499-528.
Kovacs M, Rush AJ, Beck AT, Hollon SD. Depressed outpatients treated with cognitive therapy or pharmacotherapy: a one-year follow-up. Arch Gen Psychiatry 1981;38:33-41.
Kravitz HM, Fogg L, Fawcett J, Edwards J. Antidepressant or antianxiety? A study of the efficacy of antidepressant medication. Psychiatry Res 1990;32:141-9.
Kroessler D. Relative efficacy rates for therapies of delusional depression. Conv Ther 1985;1:173-82.
Kupfer DJ. Long-term treatment of depression. J Clin Psychiatry 1991;52(Suppl 5):28-34.
Kupfer DJ, Frank E, McEachran AB, Grochocinski VJ. Delta sleep ratio: a biological correlate of early recurrence in unipolar affective disorder. Arch Gen Psychiatry 1990;47(12):1100-5.
Kupfer DJ, Frank E, Perel JM. The advantage of early treatment intervention in recurrent depression. Arch Gen Psychiatry 1989;46:771-5.
Kupfer DJ, Frank E, Perel JM, Cornes C, Mallinger AG, Thase ME, McEachran AB, Grochocinski VJ. Five-year outcome for maintenance therapies in recurrent depression. Arch Gen Psychiatry 1992;49:769-73.
Kupfer DJ, Spiker DG. Refractory depression: prediction of non-response by clinical indicators. J Clin Psychiatry 1981;42:307-12.
Lambourn J, Gill D. A controlled comparison of simulated and real ECT. Br J Psychiatry 1978;133:514-9.
Last CG, Thase ME, Hersen M, Bellack AS, Himmelhoch JM. Patterns of attrition for psychosocial and pharmacologic treatments of depression. J Clin Psychiatry 1985;46(9):361-6.
Lewinsohn PM, Antonuccio DA, Steinmetz J, Teri L. The coping with depression course: a psychoeducational intervention for unipolar depression. Eugene, OR: Castalia Press; 1984.
Lewinsohn P, Clarke G. Group treatment of depressed individuals: the "coping with depression" course. Adv Behav Res Ther 1984;6:99-114.
Liebowitz MR, Quitkin FM, Stewart JW, McGrath PJ, Harrison W, Rabkin JG, Tricamo E, Markowitz JS, Klein DF. Psychopharmacologic validation of atypical depression. J Clin Psychiatry 1984;45(7 Pt 2):22-5.
Liebowitz MR, Quitkin FM, Stewart JW, McGrath PJ, Harrison WM, Markowitz JS, Rabkin JG, Tricamo E, Goetz DM, Klein DF. Antidepressant specificity in atypical depression. Arch Gen Psychiatry 1988;45(2):129-37.
Lipper S, Murphy DL, Slater S, Buchsbaum MS. Comparative behavioral effects of clorgyline and pargyline in man: a preliminary evaluation. Psychopharmacology 1979;62:123-8.
Luborsky L. Principles of psychoanalytic psychotherapy. New York: Basic Books; 1984.
Lustman PJ, Amado H, Wetzel RD. Depression in diabetics: a critical appraisal. Compr Psychiatry 1983;1:65-74.
Lustman PJ, Griffith LS, Clouse RE. Depression in adults with diabetes: results of 5-year follow-up study. Diabetes Care 1988;11:605-12.
Lustman PJ, Griffith LS, Clouse RE, Cryer PE. Psychiatric illness in diabetes: relationship to symptoms and glucose control. J Nerv Ment Dis 1986;174:736-42.
Lykouras E, Malliaras D, Christodoulou GN, Moussas G, Christodoulou D, Tzonou A. Delusional depression: phenomenology and response to treatment. Psychopathology 1986a;19(4):157-64.
Lykouras E, Malliaras D, Christodoulou GN, Papakostas Y, Voulgari A, Tzonou A, Stefanis C. Delusional depression: phenomenology and response to treatment: a prospective study. Acta Psychiatr Scand 1986b;73(3):324-9.
Magni G, Fisman M, Helmes E. Clinical correlates of ECT-resistant depression in the elderly. J Clin Psychiatry 1988;49:405-7.
Maj M, Veltro F, Pirozzi R, Lobrace S, Magliano L. Pattern of recurrence of illness after recovery from an episode of major depression: a prospective study. Am J Psychiatry 1992;149:795-800.
Malan DH. The frontier of brief psychotherapy. New York: Plenum Press; 1976.
Malan DH. Individual psychotherapy and the science of psychodynamics. London: Butterworths; 1979.
Mandel MR, Welch CA, Mieskie M, McCormick M. Prediction of response to ECT in tricyclic-intolerant or tricyclic-resistant depressed patients. McLean Hosp J 1977;2:203-9.
Mann, J. Time-limited psychotherapy. Cambridge, MA: Harvard University Press; 1973.
Mann JJ, Georgotas A, Newton R, Gershon S. A controlled study of trazodone, imipramine, and placebo in outpatients with endogenous depression. J Clin Psychopharmacol 1981;1(2):75-80.
McDonnell-Douglas Employee Assistance Program Study, 1989, 1990 study.
McGrath PJ, Stewart JW, Harrison W, Quitkin FM. Treatment of tricyclic refractory depression with a monoamine oxidase inhibitor. Psychopharmacol Bull 1987;23:169-72.
McLean PD, Hakstian AR. Clinical depression: comparative efficacy of outpatient treatments. J Consult Clin Psychol 1979;47(5):818-36.
McLean PD, Hakstian AR. Relative endurance of unipolar depression treatment effects: longitudinal follow-up. J Consult Clin Psychol 1990;58(4):482-8.
McLean PD, Ogston K, Grauer L. A behavioral approach to the treatment of depression. J Behav Ther Exper Psychiatry 1973;4:323-30.
Medical Research Council. Clinical trial of the treatment of depressive illness. Br Med J 1965;5439:881-6.
Mendels J, Amin MM, Chouinard G, Cooper AJ, Miles JE, Remick RA, Saxena B, Secunda SK, Singh AN. A comparative study of bupropion and amitriptyline in depressed outpatients. J Clin Psychiatry 1983;44(5 Pt 2):118-20.
Miller IW, Norman WH, Bishop SB, Keitner GI, Dow MG. Cognitive-behavioral treatment of depressed inpatients. Behav Ther 1989;20:25-47.
Mindham BA. A comparison of maprotiline (Ludiomil) and amitriptyline (2). J Int Med Res 1977;5 Suppl 4:25-33.
Mindham RHS, Howland C, Shepherd M. An evaluation of continuation therapy with tricyclic antidepressants in depressive illness. Psychol Med 1973;3:5-17.
Minter RE, Mandel MR. A prospective study of the treatment of psychotic depression. Am J Psychiatry 1979a;136(11):1470-2.
Minter RE, Mandel M. The treatment of psychotic major depressive disorder with drugs and electroconvulsive therapy. J Nerv Ment Dis 1979b;167(12):726-33.
Mintz J, Mintz LI, Arruda MJ, Hwang SS. Treatments of depression and the functional capacity to work. Arch Gen Psychiatry 1992;49(10):761-8.
Montgomery SA, Dufour H, Brion S, Gailledreau J, Laqueille X, Ferrey G, Moron P, Parant-Lucena N, Singer L, Danion JM, et al. The prophylactic efficacy of fluoxetine in unipolar depression. Br J Psychiatry 1988;153(Suppl 3):69-76.
Montgomery SA, Dunbar GC. Paroxetine and placebo in the long-term maintenance of depressed patients. Paper presented at: American College of Neuropsychopharmacology; 1991 Dec; San Juan, Puerto Rico.
Moon CA, Davey A. The efficacy and residual effects of trazodone (150 mg nocte) and mianserin in the treatment of depressed general practice patients. Psychopharmacology (Berlin) 1988;95 Suppl:S7-13.
Moradi SR, Muniz CE, Belar CD. Male delusional depressed patients: response to treatment. Br J Psychiatry 1979;135:136-8.
Murphy GE, Simons AD, Wetzel RD, Lustman PJ. Cognitive therapy and nortriptyline, singly and together, in the treatment of depression. Arch Gen Psychiatry 1984;41:33-41.
Myers ED, Calvert EJ. Information, compliance and side-effects: a study of patients on antidepressant medication. Br J Clin Pharmacol 1984;17:21-5.
Neimeyer RA, Feixas G. The role of homework and skill acquisition in the outcome of group cognitive therapy for depression. Behav Ther 1990;21:281-92.
Neimeyer RA, Heath A, Strauss J. Personal reconstruction during group cognitive therapy for depression. In: Epting F, Landfield AW, editors. Anticipating personal construct psychology. Lincoln, NE: University of Nebraska Press; 1985. p. 180-95.
Neimeyer RA, Weiss ME. Cognitive and symptomatic predictors of outcome of group therapies for depression. J Cognitive Psychother: Int Q 1990;4(1):23-32.
Nelson JC, Bowers MB Jr. Delusional unipolar depression: description and drug response. Arch Gen Psychiatry 1978;35:1321-8.
Nezu AM. Efficacy of a social problem-solving therapy for unipolar depression. J Consult Clin Psychol 1986;54:196-202.
Nezu AM, Perri MG. Social problem-solving therapy for unipolar depression: an initial dismantling investigation. J Consult Clin Psychol 1989;57(3):408-13.
NIMH Consensus Development Conference Statement. Mood disorders: pharmacologic prevention of recurrences. Am J Psychiatry 1985;142:469-76.
NIMH Consensus Development Conference: The diagnosis and treatment of depression in late life. Bethesda, MD: 1991 Nov 4-6.
Nolen WA, Van De Putte JJ, Dijken WA, Kamp JS. L-5HTP in depression resistant to reuptake inhibitors: an open comparative study with tranylcypromine. Br J Psychiatry 1985;147:16-22.
Nolen WA, Van De Putte JJ, Dijken WA, Kamp JS, Blansjaar BA, Kramer HJ, Haffmans J. Treatment strategy in depression: II. MAO inhibitors in depression resistant to cyclic antidepressants: two controlled crossover studies with tranylcypromine versus L-5-hydroxytryptophan and nomifensine. Acta Psychiatr Scand 1988;78:676-83.
O'Leary KD, Beach SRH. Marital therapy: a viable treatment for depression and marital discord. Am J Psychiatry 1990;147(2):183-6.
Oren DA, Rosenthal NE. Seasonal affective disorders. In: Paykel ES, editor. Handbook of affective disorders. 2nd ed. London: Churchill Livingstone; 1992. p. 551-67.
Othmer E, Othmer SC, Stern WC, Van Wyck Fleet J. Long-term efficacy and safety of bupropion. J Clin Psychiatry 1983;44(5):153-6.
Othmer SC, Othmer E, Preskorn SH, Mac D. Differential effect of amitriptyline and bupropion on primary and secondary depression: a pilot study. J Clin Psychiatry 1988;49(8):310-2.
Overall JE, Biggs J, Jacobs M, Holden K. Comparison of alprazolam and imipramine for treatment of outpatient depression. J Clin Psychiatry 1987;48(1):15-9.
Parloff MB. Psychotherapy research evidence and reimbursement decisions: Bambi meets Godzilla. Am J Psychiatry 1982;139(6):718-27.
Paul SM, Extein I, Calil HM, et al. Use of ECT with treatment resistant depressed patients at the National Institute of Mental Health. Am J Psychiatry 1981;138:486-9.
Paykel ES, DiMascio A, Haskell D, Prusoff BA. Effects of maintenance amitriptyline and psychotherapy on symptoms of depression. Psychol Med 1975;5:67-77.
Paykel ES, DiMascio A, Klerman GL, Prusoff BA, Weissman MM. Maintenance therapy of depression. Pharmakopsychiatr Neuropsychopharmakol 1976;9(3):127-39.
Paykel ES, Myers JK, Dienelt MN, Klerman GL, Lindenthal JJ, Pepper MP. Life events and depression: a controlled study. Arch Gen Psychiatry 1969;21:753-60.
Pecheur DR, Edwards KJ. A comparison of secular and religious versions of cognitive therapy with depressed Christian college students. J Psychol Theol 1984;12(1):45-54.
Peet M, Harvey NS. Lithium maintenance: 1. A standard education programme for patients. Br J Psychiatry 1991;158:197-200.
Perry PJ, Morgan DE, Smith RE, Tsuang MT. Treatment of unipolar depression accompanied by delusions. J Affect Disord 1982;4:195-200.
Persons JB. Psychotherapy outcome studies do not accurately represent current models of psychotherapy. Am Psychol 1991;46:99-106.
Persons JB. Outcome of psychotherapy for unipolar depression. In: Giles T, editor. Effective psychotherapy: a handbook of comparative research. New York: Plenum Press; in press.
Persons JB, Burns DD, Perloff JM. Predictors of dropout and outcome in cognitive therapy for depression in a private practice setting. Cognitive Ther Res 1988;12(6):557-75.
Peselow ED, Filippi AM, Goodnick P, Barouche F, Fieve RR. The short- and long-term efficacy of paroxetine HCl: A. Data from a 6-week double-blind parallel design trial vs. imipramine and placebo. Psychopharmacol Bull 1989a;25(2):267-71.
Peselow ED, Filippi AM, Goodnick P, Barouche F, Fieve RR. The short- and long-term efficacy of paroxetine HCl: B. Data from a double-blind crossover study and from a year-long term trial vs. imipramine and placebo. Psychopharmacol Bull 1989b;25(2):272-6.
Physician's desk reference. Oradell, NJ: Medical Economics Co.; 1992.
Pilkonis PA, Frank E. Personality pathology in recurrent depression: nature, prevalence, and relationship to treatment response. Am J Psychiatry 1988;145(4):435-41.
Post RM. Transduction of psychosocial stress into the neurobiology of recurrent affective disorder. Am J Psychiatry 1992;149(8):999-1010.
Potter WZ, Murphy DL, Wehr TA, Linnoila M, Goodwin FK. Clorgyline: a new treatment for patients with refractory rapid-cycling disorder. Arch Gen Psychiatry 1982;39:505-10.
Preskorn SH, Dorey RC, Jerkovich GS. Therapeutic drug monitoring of tricyclic antidepressants. Clin Chem 1988;34:822-8.
Preskorn SH, Kent TA. Mechanisms and interventions in tricyclic antidepressant overdoses. In: Stancer HC, Garfinkel PE, Rakoff VM, editors. Guidelines for the use of psychotropic drugs. New York: Spectrum Publications; 1984. p. 63-75.
Preskorn SH, Simpson S. Tricyclic-antidepressant-induced delirium and plasma drug concentration. Am J Psychiatry 1982;139:822-3.
Preskorn SH, Weller E, Jerkovich G, Hughes CW, Weller R. Depression in children: concentration-dependent CNS toxicity of tricyclic antidepressants. Psychopharmacol Bull 1988;24:140-2.
Prien RF, Balter MB, Caffey EM Jr. Hospital surveys of prescribing practices with psychotherapeutic drugs. A critical examination. Arch Gen Psychiatry 1978;35(10):1271-5.
Prien RF, Klett CJ, Caffey EM. Lithium carbonate and imipramine in prevention of affective episodes. Arch Gen Psychiatry 1973;29:420-25.
Prien RF, Kupfer DJ. Continuation drug therapy for major depressive episodes: how long should it be maintained? Am J Psychiatry 1986;143:18-23.
Prien RF, Kupfer DJ, Mansky PA, Small JG, Tuason VB, Voss CB, Johnson WE. Drug therapy in the prevention of recurrences in unipolar and bipolar affective disorders. Report of the NIMH Collaborative Study Group comparing lithium carbonate, imipramine, and a lithium carbonate-imipramine combination. Arch Gen Psychiatry 1984;41(11):1096-1104.
Prudic J, Sackeim HA, Devanand DP. Medication resistance and clinical response to electroconvulsive therapy. Psychiatry Res 1990;31:287-96.
Prusoff BA, Weissman MM, Klerman GL, Rounsaville BJ. Research diagnostic criteria subtypes of depression: their role as predictors of differential response to psychotherapy and drug treatment. Arch Gen Psychiatry 1980;37:796-801.
Quitkin FM, Harrison W, Stewart JW, McGrath PJ, Tricamo E, Ocepek-Welikson K, Rabkin JG, Wager SG, Nunes E, Klein D. Response to phenelzine and imipramine in placebo nonresponders with atypical depression. Arch Gen Psychiatry 1991;48:319-23.
Quitkin FM, McGrath PJ, Stewart JW, Harrison WM, Tricamo E, Wager SG, Ocepek-Welikson K, Nunes E, Rabkin JG, Klein DF. Atypical depression, panic attacks, and response to imipramine and phenelzine: a replication. Arch Gen Psychiatry 1990;47:935-41.
Quitkin FM, Stewart JW, McGrath PJ, Liebowitz MR, Harrison WM, Tricamo E, Klein DF, Rabkin JG, Markowitz JS, Wager SG. Phenelzine versus imipramine in the treatment of probable atypical depression: defining syndrome boundaries of selective MAOI responders. Am J Psychiatry 1988;145(3):306-11.
Rehm LP. Behavior therapy for depression. New York: Academic Press; 1979.
Rehm LP. Psychotherapies for depression. In: Bloom BL, Schlesinger K, editors. Boulder symposium on clinical psychology: depression. Hillsdale, NJ: Erlbaum; in press.
Rehm LP, Kaslow NJ, Rabin AS. Cognitive and behavioral targets in a self-control therapy program for depression. J Consult Clin Psychol 1987;55(1):60-7.
Rehm LP, Kornblith SJ, O'Hara MW, Lamparsky DM, Romano JM, Volkin JI. An evaluation of major components in a self-control behavior therapy program for depression. Behav Modif 1981;5:459-89.
Reimherr FW, Wood DR, Byerley B, Brainard J, Grosser BI. Characteristics of responders to fluoxetine. Psychopharmacol Bull 1984;20(1):70-2.
Reynolds CF, Frank E, Perel JM, Imber SD, Cornes C, Morycz RK, Mazumdar S, Miller MD, Pollock BG, Rifai AH, et al. Combined pharmacotherapy and psychotherapy in the acute and continuation treatment of elderly patients with recurrent major depression: a preliminary report. Am J Psychiatry 1992;149(12):1687-92.
Richards HH, Midha RN, Miller S. A double-blind study of trazodone and mianserin in the treatment of depression in general practice. J Int Med Res 1982;10(3):147-56.
Rickels K, Case WG. Trazodone in depressed outpatients. Am J Psychiatry 1982;139(6):803-6.
Rickels K, Chung HR, Csanalosi IB, Hurowitz AM, London J, Wiseman K, Kaplan M, Amsterdam JD. Alprazolam, diazepam, imipramine, and placebo in outpatients with major depression. Arch Gen Psychiatry 1987;44(10):862-6.
Rickels K, Gordon PE, Jenkins BW, Perloff M, Sachs T, Stepansky W. Drug treatment in depressive illness. Dis Nerv Syst 1970;31(1):30-42.
Rickels K, Smith WT, Glaudin V, Amsterdam JB, Weise C, Settle GP. Comparison of two dosage regimens of fluoxetine in major depression. J Clin Psychiatry 1985;46(3 Pt 2):38-41.
Robin A, De Tissera S. A double-blind controlled comparison of the therapeutic effects of low and high energy electroconvulsive therapies. Br J Psychiatry 1982;141:357-66.
Robinson DS, Lerfald SC, Bennett B, Laux D, Devereaux E, Kayser A, Corcella J, Albright D. Continuation and maintenance treatment of major depression with the monoamine oxidase inhibitor phenelzine: a double-blind placebo-controlled discontinuation study. Psychopharmacol Bull 1991;27:31-9.
Roper Reports. Report to Medicaid: what people do for minor health problems. New York: Roper Organization; 1986. p. 86-8.
Ross M, Scott M. An evaluation of the effectiveness of individual and group cognitive therapy in the treatment of depressed patients in an inner city health centre. J Royal Gen Pract 1985;35:239-42.
Rost KM, Smith GR. The deliberate miscoding of major depression in the primary care setting. Paper presented at: the Society for General Internal Medicine; 1992 Apr; Washington, DC.
Roth D, Bielski R, Jones M, Parker W, Osborn G. A comparison of self-control therapy and combined self-control therapy and antidepressant medication in the treatment of depression. Behav Ther 1982;13:133-44.
Rounsaville BJ, Weissman MM, Prusoff BA. Psychotherapy with depressed outpatients: patient and process variables as predictors of outcome. Br J Psychiatry 1981;138:67-74.
Rounsaville BJ, Weissman MM, Prusoff BA, Herceg-Baron RL. Marital disputes and treatment outcome in depressed women. Compr Psychiatry 1979;20(5):483-90.
Rude SS. Relative benefits of assertion or cognitive self-control treatment for depression as a function of proficiency in each domain. J Consult Clin Psychol 1986;54(3):390-4.
Rush AJ. Pharmacotherapy and psychotherapy. In: Derogatis LR, editor. Clinical psychopharmacology. Menlo Park, CA: Addison-Wesley Publishing Co.; 1986. p. 46-67.
Rush AJ. Cognitive approaches to adherence. In: Frances AJ, Hales RJ, editors. Annual review of psychiatry. Vol. 7. Washington, DC: American Psychiatric Press; 1988. p. 625-40.
Rush AJ, Beck AT, Kovacs M, Hollon SD. Comparative efficacy of cognitive therapy and pharmacotherapy in the treatment of depressed outpatients. Cognitive Ther Res 1977;1:17-37.
Rush AJ, Cain JW, Raese J, Stewart RS, Waller DA, Debus JD. Neurological bases for psychiatric disorders. In: Rosenberg RN, editor. Comprehensive neurology. New York: Raven Press; 1991. p. 555-603.
Rush AJ, Erman MK, Schlesser MA, Roffwarg HP, Vasavada N, Khatami M, Fairchild C, Giles DE. Alprazolam versus amitriptyline in depressions with reduced REM latencies. Arch Gen Psychiatry 1985;42(12):1154-9.
Rush AJ, Hollon S, Beck AT, Kovacs M. Depression: must pharmacotherapy fail for cognitive therapy to succeed? Cognitive Ther Res 1978;2:199-206.
Rush AJ, Watkins JT. Group versus individual cognitive therapy: a pilot study. Cognitive Ther Res 1981;5(1):95-103.
Rush AJ, Weissenburger J. Melancholic symptom features: a review and options for DSM-IV. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Sackeim HA, Prudic J, Devanand DP. Treatment of medication resistant depression with electroconvulsive therapy. In: Tasman A, Goldfinger SM, Kaufman CA, editors. Annual review of psychiatry. Vol. 9. Washington, DC: American Psychiatric Press; 1990. p. 91-115.
Sackeim HA, Prudic J, Devanand DP, Decina P, Kerr B, Malitz S. The impact of medication resistance and continuation pharmacotherapy on relapse following response to electroconvulsive therapy in major depression. J Clin Psychopharmacol 1990;10:96-104.
Schatzberg AF, Rothschild AJ. Psychotic (delusional) major depression: issues for DSM-IV. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Schuckit MA, Feighner JP. Safety of high-dose tricyclic antidepressant therapy. Am J Psychiatry 1972;128(11):1456-9.
Schweizer E, Rickels K, Amsterdam JD, Fox I, Puzzuoli G, Weise C. What constitutes an adequate antidepressant trial for fluoxetine? J Clin Psychiatry 1990;51(1):8-11.
Scogin F, Jamison C, Davis N.1989;
Scogin F, Jamison C, Gochneaur K. Comparative efficacy of cognitive and behavioral bibliotherapy for mildly and moderately depressed older adults. J Consult Clin Psychol 1989;57:403-7.
Scott AIF. Which depressed patients will respond to electroconvulsive therapy? The search for biological predictors of recovery. Br J Psychiatry 1989;154:8-17.
Scott MJ, Stradling SG. Group cognitive therapy for depression produces clinically significant reliable change in community-based settings. Behav Psychother 1990;18:1-19.
Secunda SK, Katz MM, Friedman R, Schuyler D. Special report: the depressive disorders. Washington, DC: National Institute of Mental Health, US Government Printing Office; 1973.
Selmi PM, Klein MH, Greist JH, Sorrell SP, Erdman HP. Computer-administered cognitive-behavioral therapy for depression. Am J Psychiatry 1990;147(1):51-6.
Seltzer A, Roncari I, Garfinkel P. Effect of patient education on medication compliance. Can J Psychiatry 1980;25:638-45.
Shapiro DR, Quitkin FM, Fleiss JL. Response to maintenance therapy in bipolar illness: effect of index episode. Arch Gen Psychiatry 1989;46(5):401-5.
Shapiro S, Skinner EA, Kessler LG, von Korff M, German PS, Tischler GL, Leaf PJ, Benham L, Cottler L, Regier DA. Utilization of health and mental health services: three epidemiologic catchment sites. Arch Gen Psychiatry 1984;41:971-8.
Shaw BF. Cognitive-behavior therapies for major depression: current status with an emphasis on prophylaxis. Psychiatr J Univ Ottawa 1989;14(2):403-8.
Shaw BF, Elkin I, Vallis TM, Dobson SD, Olmsted M. Therapist competency and adherence ratings with prediction of outcome in the cognitive therapy for depression. Unpublished manuscript, 1993.
Shaw BF, Olmsted M. Competency ratings in relation to protocol adherence and clinical outcome. Paper presented at: The Society for Psychotherapy Research; 1989 Jun: Toronto, Canada.
Shea MT, Elkin I, Imber SD, Sotsky SM, Watkins JT, Collins JF, Pilkonis PA, Beckham E, Glass DR, Dolan RT, et al. Course of depressive symptoms over follow-up: findings from the NIMH Treatment of Depression Collaborative Research Program. Arch Gen Psychiatry 1992;49(10):782-7.
Shea MT, Pilkonis PA, Beckham E, Collins JF, Elkin I, Sotsky SM, Docherty JP. Personality disorders and treatment outcome in the NIMH Treatment of Depression Collaborative Research Program. Am J Psychiatry 1990;147(6):711-8.
Sher TG, Baucom DH, Larus JM. Communication patterns and response to treatment among depressed and nondepressed maritally distressed couples. J Fam Psychol 1990;4(1):63-79.
Simons AD, Murphy GE, Levine JL, Wetzel RD. Cognitive therapy and pharmacotherapy for depression: sustained improvement over one year. Arch Gen Psychiatry 1986;43:43-8.
Simpson GM, Lee JH, Cucuilc Z, Kellner R. Two doses of imipramine in hospitalized depressives. Arch Gen Psychiatry 1976;33(9):1093-1102.
Soloff PH, George A, Nathan RS, Schulz PM. Characterizing depression in borderline patients. J Clin Psychiatry 1987;48:155-7.
Sotsky SM, Glass DR, Shea MT, Pilkonis PA, Collins JF, Elkin I, Watkins JT, Imber SD, Leber WR, Moyer J, et al. Patient predictors of response to psychotherapy and pharmacotherapy: findings in the NIMH Treatment of Depression Collaborative Research Program. Am J Psychiatry 1991;148(8):997-1008.
Spiker DG, Weiss JC, Dealy RS, Griffin SJ, Hanin I, Neil JF, Perel JM, Rossi AJ, Soloff PH. The pharmacological treatment of delusional depression. Am J Psychiatry 1985;142(4):430-6.
Stein MK, Rickels K, Weise CC. Maintenance therapy with amitriptyline: a controlled trial. Am J Psychiatry 1980;137(3):370-1.
Steinmetz JL, Lewinsohn PM, Antonuccio DO. Prediction of individual outcome in a group intervention for depression. J Consult Clin Psychol 1983;51(3):331-7.
Stern SL, Rush AJ, Mendels J. Toward a rational pharmacotherapy of depression. Am J Psychiatry 1980;187:545-52.
Stern WC, Harto-Truax N, Bauer N. Efficacy of bupropion in tricyclic-resistant or intolerant patients. J Clin Psychiatry 1983;44(5 Pt 2):148-52.
Steuer JL, Mintz J, Hammen CL, Hill MA, Jarvik LF, McCarley T, Motoike P, Rosen R. Cognitive-behavioral and psychodynamic group psychotherapy in treatment of geriatric depression. J Consult Clin Psychol 1984;52(2):180-9.
Stoudemire A, Frank R, Hedemark N, Kamlet M, Blazer D. The economic burden of depression. Gen Hosp Psychiatry 1986;8:387-94.
Strober M. Familial aspects of depressive disorder in early adolescence. In: Weller EB, Weller RA, editors. Current perspectives on major depressive disorders in children. Washington, DC: American Psychiatric Press; 1984. p. 38-48.
Strober M, Carlson G. Bipolar illness in adolescents with major depression: clinical, genetic, and psychopharmacologic predictors in a three- to four-year prospective followup investigation. Arch Gen Psychiatry 1982;39:549-55.
Strupp HH, Binder JL. Psychotherapy in a new key. New York: Basic Books; 1984.
Tamayo M, Fernandez de Gatta MM, Gutierrez JR, Carcia MJ, Dominguez-Fil A. High levels of tricyclic antidepressants in conventional therapy: determinant factors. Int J Clin Pharmacol Ther Toxicol 1988;26:495-9.
Teri L, Lewinsohn PM. Individual and group treatment of unipolar depression: comparison of treatment outcome and identification of predictors of successful treatment outcome. Behav Ther 1986;17:215-28.
Terman M, Williams JBW, Terman JS. Light therapy for winter depression: a clinician's guide. In: Keller P, editor. Innovations in clinical practice: a source book. Sarasota, FL: Pro Resource; 1991. p. 179-221.
Thase ME, Carpenter L, Kupfer DJ, Frank E. Clinical significance of reversed vegetative subtypes of recurrent major depression. Psychopharmacol Bull 1991;27:17-22.
Thase ME, Frank E, Mallinger A, Hamer T, Kupfer DJ. Treatment of imipramine-resistant recurrent depression: III. Efficacy of monoamine oxidase inhibitor. J Clin Psychiatry 1992;53(1):5-11.
Thase ME, Hersen M, Bellack AS, Himmelhoch JM, Kupfer DJ. Validation of a Hamilton subscale for endogenomorphic depression. J Affect Disord 1983;5:267-78.
Thase ME, Mallinger AG, McKnight D, Himmelhoch JM. Treatment of imipramine-resistant recurrent depression: IV. A double-blind, cross-over study of tranylcypromine in anergic bipolar depression. Am J Psychiatry 1992;149(2):195-8.
Thompson LW, Gallagher DE. Efficacy of psychotherapy in the treatment of late-life depression. Psychological treatment of unipolar depression: special issue. Adv Behav Res Ther 1984;6(2):127-39.
Thompson LW, Gallagher DE, Breckenridge JS. Comparative effectiveness of psychotherapies for depressed elders. J Consult Clin Psychol 1987;55(3):385-90.
Thompson LW, Gallagher D, Czirr R. Personality disorder and outcome in the treatment of late-life depression. J Geriatr Psychiatry 1988;21(2):133-46.
Turner RW, Wehl CK. Treatment of unipolar depression in problem drinkers. Adv Behav Res Ther 1984;6:115-25.
Usaf SO, Kavanagh DJ. Mechanisms of improvement in treatment for depression: test of a self-efficacy and performance model. J Cognitive Psychother: Int Q 1990;4(1):51-70.
USP. Drug information for the health care professional. Volumes 1A, 1B. 12th ed. Rockville, MD: US Pharmacopeial Convention; 1992.
van Gent EM, Zwart FM. Psychoeducation of partners of bipolar-manic patients. J Affect Disord 1991;21(1):15-8.
von Korff M, Ormel J, Katon W, Lin E. Disability and depression among high utilizers of health care: a longitudinal analysis. Arch Gen Psychiatry 1992;49:91-100.
Voris JC, Morin C, Kiel JS. Monitoring outpatients' plasma antidepressant-drug concentrations as a measure of compliance. Am J Hosp Pharm 1983;40:119-29.
Watson M. Psychosocial intervention with cancer patients: a review. Psychol Med 1983;13:839-46.
Weisman A, Worden J. The existential plight in cancer: significance of the first 100 days. Psychiatry Med 1976-1977;7:1-15.
Weissman MM. The psychological treatment of depression: evidence for the efficacy of psychotherapy alone, and in comparison with, and in combination with pharmacotherapy. Arch Gen Psychiatry 1979;36:1261-9.
Weissman MM, Jarrett RB, Rush AJ. Psychotherapy and its relevance to the pharmacotherapy of major depression: a decade later (1976-1985). In: Meltzer H, editor. Psychopharmacology: the third generation of progress. New York: Raven Press; 1987.
Weissman MM, Kasl SV, Klerman GL. Follow-up of depressed women after maintenance treatment. Am J Psychiatry 1976;133:757-60.
Weissman MM, Klerman GL, Prusoff BA, Sholomskas D, Padian N. Depressed outpatients: results one year after treatment with drugs and/or interpersonal psychotherapy. Arch Gen Psychiatry 1981;38:51-5.
Weissman MM, Prusoff BA, DiMascio A, Neu C, Goklaney M, Klerman GL. The efficacy of drugs and psychotherapy in the treatment of acute depressive episodes. Am J Psychiatry 1979;136(4B):555-8.
Wells KB. Depression as a tracer condition for the national study of medical care outcomes background review. Santa Monica: RAND; 1985.
Wells KB, Golding JM, Burnam MA. Psychiatric disorder and limitations in physical functioning in a sample of the Los Angeles general population. Am J Psychiatry 1988a;145:712-7.
Wells KB, Golding JM, Burnam MA. Psychiatric disorder in a sample of the general population with and without chronic medical conditions. Am J Psychiatry 1988b;145:976-81.
West ED. Electric convulsion therapy in depression: a double-blind controlled trial. Br Med J 1981;282(6261):355-7.
Wilson PH. Cognitive-behavior therapy for depression: empirical findings and methodological issues in the evaluation of outcome. Behav Change 1989;6(2):85-95.
Winokur G. Familial (genetic) subtypes of pure depressive disease. Am J Psychiatry 1979;136:911-3.
Winokur G. Mania and depression, a classification of syndrome and disease. Baltimore: Johns Hopkins University Press; 1991.
Winokur G, Kadrmas A. A polyepisodic course in bipolar illness: possible clinical relationships. Compr Psychiatry 1989;30:121-7.
Winokur G, Wesner R. From unipolar depression to bipolar illness: 29 who changed. Acta Psychiatr Scand 1987;76:59-63.
Winsauer HJ, O'Hair DE. Rapid onset of action of amoxapine in depressive illness. Curr Ther Res 1984;35(5):815-25.
Wolberg LR. Short-term psychotherapy. New York: Grune & Stratton; 1967.
Woody GE, Luborsky L, McLellan AT, O'Brien CP, Beck AT, Blaine J, Herman I, Hole A. Psychotherapy for opiate addicts. Does it help? Arch Gen Psychiatry 1983;40(6)[JC:72c]:639-45.
Youssel FA. Youssef FA. Compliance with therapeutic regimens: a follow-up study for patients with affective disorders. J Adv Nurs 1983;8:513-7.
Yudofsky SC. Electroconvulsive therapy in general hospital psychiatry: a focus on new indications and technologies. Gen Hosp Psychiatry 1981;3(4):292-6.
Zuckerman DM, Prusoff BA, Weissman MM, Padian NS. Personality as a predictor of psychotherapy and pharmacotherapy outcome for depressed outpatients. J Consult Clin Psychol 1980;48(6):730-5.