# Dedication

Depression in Primary Care is dedicated to the memory of Gerald L. Klerman, MD, who passed away while serving as one of our scientific reviewers. Dr. Klerman, in his lifetime of research, teaching, and clinical work, and in his years of government service as the administrator of the Alcohol, Drug Abuse, and Mental Health Administration, Public Health Service, Washington, DC (1977-80), worked diligently to develop scientifically based information to help clinicians better serve their patients. We remain indebted to him for his contribution to our panel and to the field of psychiatry in general.