# Contributors

These guidelines could not have been developed without the expertise and assistance of many types of contributors who, together, made the effort feasible. All of those listed here willingly assisted in the intense effort required to develop guidelines on an issue as complex as the appropriate treatment of major depressive disorder. The resulting document reflects the many important interactions that occurred during the guideline development process.

## Depression Guideline Panel Members: Biosketches

- A. John Rush, MD, Chair
- Betty Jo Hay Distinguished Chair in Mental Health Professor and Vice Chairman for Research, Department of Psychiatry
- University of Texas Southwestern Medical Center
- Dallas, Texas

Dr. Rush received his BA from Princeton University and his MD from the College of Physicians and Surgeons of Columbia University.

He is currently the Director of the Mental Health Clinical Research Center, an NIMH-funded center studying the biology, psychology, pharmacology, and psychotherapy of mood disorders. Dr. Rush has published extensively on both the psychology and biology of depression. He has received several NIMH grants to study depression and has helped develop and study the efficacy of cognitive therapy in treatment of depressed outpatients. His research has sought to identify biologic and psychological predictors of specific treatment responses, as well as relapse and recurrence. He serves as the Chair of the DSM-IV Work Group on Mood Disorders for the American Psychiatric Association.

Dr. Rush is a Fellow of the American College of Psychiatry, the American Psychiatric Association, and the American College of Neuropsychopharmacology. He is Past President of the Society for Psychotherapy Research.

- William E. Golden, MD
- Director, General Internal Medicine
- Associate Professor, Department of Medicine
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas

Dr. Golden received his AB from Brown University (1975) and his MD from Baylor College of Medicine (1978). He completed his internal medicine residency and chief residency at Rush-Presbyterian St. Luke's Medical Center in Chicago (1983). Dr. Golden is Director of the Quality Assurance Research and Education Center, Director of the Division of General Internal Medicine, and Associate Professor of Medicine at the University of Arkansas for Medical Sciences. He is currently Chairman of the Quality Assurance Committee of University Hospital. He has had several funded projects in quality assurance and has expertise in perioperative care and medical informatics. He has authored more than 40 journal articles and book chapters on perioperative care, medical education, and quality improvement.

Dr. Golden is a trustee of the American Society of Internal Medicine and a member of the board of directors of the American Medical Review Research Center. He serves on the American Medical Association Council on Medical Education and has recently been appointed to the Liaison Committee on Medical Education. He is a member of many internal medicine societies and has served numerous roles in educational activities and policy-making matters for these organizations.

- Gladys Walton Hall, PhD, MSW
- Associate Professor, School of Social Work
- Howard University
- Washington, District of Columbia

Dr. Hall received her BS from Morgan State University (1966), MSW from the University of Connecticut (1971), and PhD from the University of Maryland (1982). She recently completed a post-doctoral fellowship at the National Institute of Mental Health (1990).

Dr. Hall teaches clinical social work methods courses and is a licensed clinical social worker with experience in the private and public sectors. Her private practice is in a comprehensive medical setting and includes the treatment of depressed women. She has authored several publications in the area of depression (childhood depression) and served on various professional boards, both national and local (including the D.C. Mental Health Association). Her research focus is on the psychosocial factors related to the co-morbidity of depression and conduct disorder among children.

- Col. Moses Herrera, MD
- Chief, Primary Care Clinic
- Robins Air Force Base Hospital
- Robins Air Force Base, Georgia

Dr. Herrera is a Fellow of the American Academy of Family Practice. He has many years of experience in the practice of family medicine, including obstetrics, geriatrics, pediatrics, and adolescent medicine, as well as in short-term psychotherapy and in the diagnosis and treatment of depression. He has served on the Mental Health Committee of the American Academy of Family Practice. With his experience, Dr. Herrera can speak with particular regard to the utility of guidelines as they may be applied to family practice in military medicine.

- Artie Houston
- Consumer Representative
- Fort Worth, Texas

Mrs. Houston represents patients (consumers). She has lived successfully with manic-depressive illness, which was diagnosed in 1968. She played a prominent role in the establishment of the National Depressive and Manic-Depressive Association (NDMDA) and served as its executive vice president and president in 1988-89. Mrs. Houston founded the first NDMDA chapter in Tarrant County, Texas, and served as its president for 2 years. She has a background in business and public relations. She served for 15 years as the business director of a large blood center in Fort Worth, Texas. Mrs. Houston has an extensive history of volunteer work in the areas of depression, manic-depressive illness, and hemophilia.

- Roger G. Kathol, MD
- Professor of Psychiatry and Internal Medicine
- University of Iowa Hospitals and Clinics
- Iowa City, Iowa

Dr. Kathol received his BA from the University of Kansas (1970) and his MD from the University of Kansas School of Medicine (1974). He completed his residency in internal medicine at the University of Iowa (1978) and his residency in psychiatry at the University of Iowa (1980). He completed a 1-year fellowship in endocrinology at the University of Otago in Wellington, New Zealand (1981).

Dr. Kathol is the director of the combined Internal Medicine/Psychiatry Unit and the General Hospital Psychiatry Services at the University of Iowa Hospitals and Clinics. He currently teaches both psychiatrists and internists about the diagnosis and treatment of medical and psychiatric disorders in patients with complex and combined medical/psychiatric difficulties. He has received NIMH and private foundation grants for clinical research on depressive disorders in the medically ill, on endocrine changes in patients with primary depression, and on pharmacokinetic drug interactions. His research has contributed to the understanding of depression in the medically ill, as well as the potential relationship of hypothalamic-pituitary-adrenal axis dysfunction in patients with primary affective disorder.

Dr. Kathol has lectured widely, is on the editorial board of several journals, holds membership on the boards of national organizations, and is published widely in the area of psychiatric pathology as seen in medically ill patients. He is board-certified in both internal medicine and psychiatry, and is a Fellow of the American College of Physicians, the American Psychiatric Association, and the American Academy of Psychosomatic Medicine. He is the current president of the Academy of Clinical Psychiatry and is a founding officer of the Association of Medicine and Psychiatry.

- Wayne Katon, MD
- Professor of Psychiatry
- Chief of Consultation-Liaison Psychiatry
- University of Washington Medical School
- Seattle, Washington

Dr. Katon received his BA from the University of Vermont (1971) and his MD from the University of Oregon (1976). He completed his residency in psychiatry at the University of Washington (1979).

Dr. Katon is Chief of the Division of Consultation-Liaison at the University of Washington and head of the Psychiatry Liaison Service to Family Medicine at University and Providence Medical Centers. Dr. Katon received the American Academy of Family Practice Award for Excellence in Teaching. He has taught medical students, psychiatric residents, and family medicine practitioners in the area of psychiatric disorders in family practice and primary care. He has received independent NIMH funding for the study of depression and chronic tinnitus, a randomized trial of psychiatric consultation for patients who are high medical service utilizers, and a randomized trial of psychiatric consultation in treatment of major depression in primary care.

Dr. Katon has published widely in the area of psychopathology (depression, panic disorders, and somatization) in the primary care setting. He has authored more than 100 journal articles and chapters and a book commissioned by NIMH entitled Panic Disorder in the Medical Setting. His research has sought to identify the psychological and social factors associated with medically unexplained somatic symptoms (chest pain, back pain, irritable bowel syndrome, tinnitus, pelvic pain, and dizziness). He is a recognized national and international authority on psychiatric disorders in family practice and general internal medicine.

- Catherine L. Matchett, MD
- Matchett Medical Center, President
- Grapevine, Texas

Dr. Matchett is a Fellow of the American Academy of Family Practice in private practice, who serves approximately 3,500 families in the North Texas area. She completed a rotating internship and 2 years in a psychiatry residency, passing the written boards in psychiatry before completing a amily practice residency.

Dr. Matchett is Vice President of the Dallas Chapter of the American Academy of Family Practice. She has a strong interest in preventive medicine and patient education. She has developed and lectured on the utilization of patient education materials and educational methods to facilitate detection and recognition of a wide variety of common health problems, including several disorders that are commonly missed or misdiagnosed by primary care physicians, including depression, anxiety disorders, premenstrual syndrome, and headache disorders. These materials are used to engage patient participation in the process of identification and translation of symptoms into a proper diagnosis so that recognized treatment strategies may be employed. There is an assumption that patient compliance with treatment increases when the patient is educated and actively involved in the treatment process.

- Frederick Petty, PhD, MD
- Associate Professor, Department of Psychiatry
- Veterans Administration Medical Center
- University of Texas Southwestern Medical Center
- Dallas, Texas

Dr. Petty received his PhD from the Georgia Institute of Technology (1971) and his MD from the University of Tennessee (1976). He completed his residency in psychiatry at the University of Iowa (1980).

Dr. Petty is the recipient of a Research Career Development Award from the Department of Veterans Affairs. He was the Director of the Consultation/Liaison Service at both the Iowa City and Dallas Department of Veterans Affairs Medical Centers. He conducts both basic and clinical research on the biology of stress and depression, as well as on biologic markers for alcoholism. Dr. Petty has received independent, peer-reviewed funding to conduct his research from the Veterans Administration Merit Review Board, NIMH, and NIAAA. He has lectured widely to family practice and general internal medicine physicians regarding the differential diagnosis and management of mood disorders. Dr. Petty is Director of the Depression Clinic at the Department of Veterans Affairs Medical Center in Dallas.

- Herbert C. Schulberg, PhD
- Professor of Psychiatry, Psychology and Medicine
- University of Pittsburgh School of Medicine
- Pittsburgh, Pennsylvania

Dr. Schulberg received his BA from Yeshiva College (1955), his PhD from Columbia University, and his MS Hygiene from the Harvard School of Public Health (1963). He completed 2 years of pre-doctoral internships in clinical psychology at several Veterans Administration facilities.

Dr. Schulberg is Director of the Primary Care Consultation Program at the Western Psychiatric Institute and Clinic. He is a Fellow of the American Psychological Association, and was previously president of the American College of Mental Health Administration and a Visiting Scientist at the NIMH. He has published more than 125 peer-reviewed articles, chapters, and books that focus on the delivery and evaluation of psychiatric services, as well as the recognition, differential diagnosis, and treatment of depression and other psychiatric disorders in the primary care setting. Dr. Schulberg is a recognized national authority in this area. He has received several NIMH grants that support his research efforts. Presently, Dr. Schulberg is directing an NIMH-funded 4-year study of the clinical efficacy and cost efficiency of various treatments for major depression in primary care practice.

- G. Richard Smith, Jr., MD
- Professor and Director
- Centers for Mental Healthcare Research
- VA HSR & D -- Field Program for Mental Health
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas

Dr. Smith received his MD from the University of Arkansas (1977), where he completed his residency in psychiatry. He was a Fellow in Psychiatry and Medicine at the University of Rochester (1980-81). He has served as residency director in the Department of Psychiatry at the University of Arkansas. He has published in the areas of alexithymia, somatization disorder, consultation-liaison, and immunology. He has received NIMH and Robert Wood Johnson Foundation research support for studies of somatization disorder and psychosocial disabilities associated with myocardial infarction. He has been developing disease-specific outcome modules for psychiatric conditions.

Dr. Smith currently serves as Chair of the NIMH Initial Review Group on Mental Health Services Research. He is Director of the Centers for Mental Healthcare Research, which include the NIMH Center for Rural Mental Healthcare Research and the Veterans Affairs Field Program for Mental Health.

- Gail Wiscarz Stuart, PhD, RN, CS
- Associate Professor and Chief, Division of Psychiatric Nursing
- Department of Psychiatry and Behavioral Sciences
- Professor, College of Nursing
- Medical University of South Carolina
- Charleston, South Carolina

Dr. Stuart received her MS in psychiatric nursing from the University of Maryland (1973) and her PhD in behavioral sciences from Johns Hopkins University (1985). She is a certified specialist in adult psychiatric and mental health nursing from the American Nurses Association and maintains a private practice of psychotherapy.

Dr. Stuart's clinical and research interests involve the study of depression, anxiety disorders, and mental health care delivery systems. As Chief of the Division of Psychiatric Nursing, in the Department of Psychiatry, Dr. Stuart is responsible for overseeing the clinical inpatient units at the Institute of Psychiatry. She is also the coordinator of the graduate program in psychiatric nursing at the Medical University of South Carolina in Charleston.

Dr. Stuart has received multiple honors and awards for her work from a large number of organizations and is a Fellow of the American Academy of Nursing. She serves on the NIMH Task Force on Psychiatric Nursing and the NIMH Research Resource Panel for the Severely Mentally Ill, among other national appointments. Dr. Stuart has been the principal investigator or coinvestigator on several independent research grants, including studies of the pharmacotherapy and childhood environments of patients with panic disorder, bulimia, and depression. She has written several nationally recognized textbooks on psychiatric nursing and has a substantial list of peer-reviewed journal publications in both the areas of psychiatric disorders and the role of nursing in health care delivery.

## Reviewing Consultants for Diagnosis Issues [1]

- The Psychobiology of Fibromyalgia (Fibrositis) Syndrome
- I. John Russell, MD, PhD
- Department of Medicine University of Texas Health Science Center at San Antonio
- San Antonio, Texas
- Screening Laboratory Evaluation in Psychiatric Patients: A Critical Review
- Theodore J. Anfinson, MD
- Department of Internal Medicine University of Iowa College of Medicine
- Iowa City, Iowa
- Roger G. Kathol, MD
- University of Iowa Hospitals and Clinics
- Iowa City, Iowa
- Screening Ambulatory Depressives for Causative Medical Illnesses: The Example of Thyroid Functioning
- Mark S. Bauer, MD
- Department of Psychiatry University of Pennsylvania
- Philadelphia, Pennsylvania
- Chronic Fatigue Syndrome
- Susan S. Beland, MD
- Division of General Internal Medicine University of Arkansas for Medical Sciences
- Little Rock, Arkansas
- Depression vs. Dementia
- Dan G. Blazer II, MD, PhD
- Department of Psychiatry Duke University Medical Center
- Durham, North Carolina
- Recognition and Detection of Bipolar Disorder
- Charles L. Bowden, MD
- Linder Funderburg, MD
- University of Texas Health Science Center at San Antonio
- San Antonio, Texas
- Depression and Coronary Artery Disease
- Robert M. Carney, PhD
- Washington University School of Medicine
- St. Louis, Missouri
- Depression Rating Scales
- W. Edward Craighead, PhD
- Duke University and Duke University Medical Center
- Durham, North Carolina
- Treatment of Depression in Patients with Co-morbid Eating Disorders
- Michael J. Devlin, MD
- B. Timothy Walsh, MD
- Columbia University College of Physicians and Surgeons
- New York, New York
- Completed Suicide: A Review
- Arlene P. Hegg, MD
- Boulder, Colorado
- Critical Review of Data Supporting Affective Disorder Caused by Nonpsychotropic Medication
- Teresa D. Long, MD
- Roger G. Kathol, MD
- University of Iowa Hospitals and Clinics
- Iowa City, Iowa
- Depression in Adults with Diabetes
- Patrick J. Lustman, PhD
- Department of Psychiatry Washington University School of Medicine
- St. Louis, Missouri
- Depression in the Cancer Patient
- Jimmie C. Holland, MD
- Chief, Psychiatric Services
- Memorial Sloan-Kettering
- New York, New York
- The Depressed Alcoholic: Clinical Features and Medical Management
- Frederick Petty, PhD, MD
- Associate Professor, Department of Psychiatry
- Veterans Administration Medical Center
- University of Texas Southwestern Medical Center
- Dallas, Texas
- The Detection of Personality Variables Relevant to the Treatment of Depression in Primary Care: A Review of the Literature
- Bruce Pfohl, MD, MS
- University of Iowa College of Medicine
- Iowa City, Iowa
- Douglas R. Langbehn, MD, MS
- University of Iowa Department of Psychiatry
- Iowa City, Iowa
- Treatment of Depression in the Elderly
- Charles F. Reynolds III, MD
- University of Pittsburgh School of Medicine
- Western Psychiatric Institute and Clinic
- Pittsburgh, Pennsylvania
- Treatment of Depressive Disorders Following Stroke
- Robert G. Robinson, MD
- University of Iowa College of Medicine
- Iowa City, Iowa
- Epidemiology of Depression in Primary Care
- Herbert C. Schulberg, PhD
- University of Pittsburgh School of Medicine
- Pittsburgh, Pennsylvania
- Wayne Katon, MD
- Professor of Psychiatry Chief of Consultation-Liaison Psychiatry
- University of Washington Medical School
- Seattle, Washington
- Self-Report and Projective Measures in the Detection, Differential Diagnosis, and Management of Depressive Disorders in Outpatient Primary Care Settings
- Brian F. Shaw, PhD
- University of Toronto Toronto Hospital and the Hospital for Sick Children
- Toronto, Canada
- The Epidemiology and Treatment of Coexisting Depression, Somatoform Disorders, Somatization, and Pain
- G. Richard Smith Jr., MD
- Professor and Vice Chair of Psychiatry
- University of Arkansas for Medical Sciences Centers for Mental Health Care Research
- Little Rock, Arkansas
- Depressive Syndromes and Their Treatment in Children and Adolescents
- Elizabeth Weller, MD
- Ronald A. Weller, MD
- Ohio State University
- Columbus, Ohio
- Diagnostic Co-morbidity in Anxiety and Mood Disorders: Community and Primary Care Populations
- Richard E. Zinbarg, PhD
- University of Oregon
- Eugene, Oregon
- David H. Barlow, PhD
- Department of Psychiatry
- State University of New York at Albany
- Albany, New York

[1] Being listed in this section does not necessarily imply endorsement of the guideline.

## Scientific Reviewers [2]

- Hagop S. Akiskal, MD
- Senior Science Advisor,
- Office of the Director
- National Institute of Mental Health
- Rockville, Maryland
- Deborah Allen, MD
- Professor and Chairman,
- Department of Family Medicine
- Indiana University School of Medicine
- Indianapolis, Indiana
- Kenneth Z. Altshuler, MD *
- Professor and Chairman,
- Department of Psychiatry
- University of Texas
- Southwestern Medical Center
- Dallas, Texas
- Aaron T. Beck, MD*
- Professor, Department of Psychiatry
- University of Pennsylvania
- Philadelphia, Pennsylvania
- W. Eugene Broadhead, MD, PhD, FAAFP
- Associate Professor, Department of Community and Family Medicine
- Duke University Medical Center
- Durham, North Carolina
- C. Robert Cloninger, MD*
- Washington University Medical School
- St. Louis, Missouri
- Allen J. Frances, MD*
- Professor and Chairman,
- Department of Psychiatry
- Duke University Medical Center
- Durham, North Carolina
- Ellen Frank, PhD*
- University of Pittsburgh School of Medicine
- Western Psychiatric Institute and Clinic
- Pittsburgh, Pennsylvania
- Jack Froom, MD
- Professor,
- State University of New York at Stony Brook
- Stony Brook, New York
- Junius J. Gonzales, MD
- Chief, Primary Care Research Program
- Services Research Branch
- National Institute of Mental Health
- Rockville, Maryland
- Frederick K. Goodwin, MD
- Director,
- National Institute of Mental Health
- Bethesda, Maryland
- Philip S. Holtzman, PhD*
- Harvard University
- Cambridge, Massachusetts
- Neil Jacobson, PhD
- Professor, Department of Psychology
- Center for Clinical Research University of Washington
- Seattle, Washington
- Lewis L. Judd, MD
- Mary Gilman Marston Professor and Chair,
- Department of Psychiatry
- UCSD School of Medicine
- La Jolla, California
- T. Byram Karasu, MD
- Professor of Psychiatry
- Albert Einstein College of Medicine Bronx Municipal Hospital Center Jacobi Hospital
- Bronx, New York
- Donald F. Klein, MD
- Columbia University, College of Physicians & Surgeons
- New York, New York
- Gerald Klerman, MD (deceased)
- Professor, Department of Psychiatry Director of Research
- New York Hospital/ Cornell Medical Center Payne Whitney Clinic
- New York, New York
- Rodger Kobes, MD,PhD*
- Timberlawn Psychiatric Hospital
- University of Texas Southwestern Medical Center
- Dallas, Texas
- Helena Chmura Kraemer, PhD
- Stanford University
- Stanford, California
- David J. Kupfer, MD
- Western Psychiatric Institute and Clinic
- University of Pittsburgh
- Pittsburgh, Pennsylvania
- Jerome Levine, MD*
- Department of Psychiatry (MPRC)
- University of Maryland School of Medicine
- Baltimore, Maryland
- William T. McKinney, MD*
- University of Wisconsin School of Medicine
- Madison, Wisconsin
- Kathleen Merikangas, PhD*
- Yale University School of Medicine
- New Haven, Connecticut
- Deborah M. Nadzam, PhD, RN*
- Associate Director of Outcomes Research and Development
- Joint Commission on Accreditation of Healthcare Organizations
- Oak Brook Terrace, Illinois
- Robert M. Post, MD*
- National Institute of Mental Health
- Bethesda, Maryland
- Lon S. Schneider, MD*
- University of Southern California School of Medicine
- Los Angeles, California
- Myrna M. Weissman, PhD*
- Columbia University
- New York, New York
- Thomas N. Wise, MD
- Professor of Psychiatry
- Georgetown University
- Washington, District of Columbia

[2] Being listed in this section does not necessarily imply endorsement of the guideline. * Scientific Reviewer, Group II.

## Organizations and Individuals Providing Peer and Pilot Review [3]

- American Nurses Association
- Washington, District of Columbia
- Contact: Karen O'Connor, MA, RN
- Sandra E. Benter, DNSC, RN, CS
- Psychotherapy and Consultation Practice
- Owings Mills, Maryland
- John M. Davis, MD
- Illinois State Psychiatric Institute
- Chicago, Illinois
- David L. Dunner, MD
- Professor, Department of Psychiatry
- University of Washington
- Seattle, Washington
- William H.M. Finney, MD, MPH
- Shepherd's Clinic
- Baltimore, Maryland
- Terry E. Fitzgerald
- National Council,
- Community Mental Health Centers
- Rockville, Maryland
- Frederick K. Goodwin, MD
- Director,
- National Institute of Mental Health
- Bethesda, Maryland
- Edgar Heim, MD
- Professor and Co-chair
- Psychiatrische Univ. Poliklinik
- Bern, Switzerland
- Shirley Hibbeln
- Education Consultant
- National Depressive and Manic-Depressive Association
- Chicago, Illinois
- Robert M.A. Hirschfeld, MD
- Professor and Chairman, Department of Psychiatry
- University of Texas Medical Branch
- Galveston, Texas
- IMCARE Practice Guidelines Network
- IMCARE (Internal Medicine Center to Advance Research and Education)
- American Society of Internal Medicine
- Washington, District of Columbia
- Contact: Bernard M. Rosof, MD, President
- Betty F. King Executive Director
- Harold A. Kaminetzky, MD, FACOG
- Director, Practice Activities
- American College of Obstetricians and Gynecologists
- Washington, District of Columbia
- Gerald Klerman, MD (deceased)
- President
- Association for Clinical Psychosocial Research
- Don R. Lipsitt, MD
- President,
- American Association of General Hospital Psychiatrists
- Cambridge, Massachusetts
- Russ Newman, PhD, JD
- Deputy Executive Director for Professional Practice
- American Psychological Association
- Washington, District of Columbia
- Pharmaceutical Manufacturers Association Health Outcomes Work Group
- Washington, District of Columbia
- Contact: Hugh H. Tilson, MD, DrPH
- Harold Alan Pincus, MD
- American Psychiatric Association
- Washington, District of Columbia
- John B. Reichman, MD
- American Academy of Clinical Psychiatry
- Pocatello, Idaho
- Lorraine Richter, BS
- Education Chairman
- National Depressive and Manic-Depressive Association
- Chicago, Illinois
- Joseph A. Rogers
- Mental Health Association of Southeastern Pennsylvania
- Philadelphia, Pennsylvania
- Peter M. Silberfarb, MD
- Dartmouth Medical School
- Dartmouth Hitchcock Medical Center
- Lebanon, New Hampshire
- Jeff Susman, MD
- Department of Family Medicine
- University of Nebraska Medical Center
- Omaha, Nebraska
- Robert L. Thomas
- National Association of Private Psychiatric Hospitals
- Washington, District of Columbia
- Joyce E. Thompson, CNM, DrPH, FAAN
- University of Pennsylvania School of Nursing
- Philadelphia, Pennsylvania

[3] Being listed in this section does not necessarily imply endorsement of the guideline.

## Organizations and Individuals Providing Additional Scientific, Technical, and Administrative Support

- University of Texas Southwestern Medical Center
- Dallas, Texas
- M. Trivedi, MD,
- Scientific Assistant to the Chair
- M. White, MM, Project Manager
- L. Arnold
- W. Hendrickse, MD, MRCP
- G. Kramer
- D. Savage
- Agency for Health Care Policy and Research,
- Rockville, Maryland
- J.J. Clinton, MD, Administrator
- K. McCormick, PhD, RN,
- Director, Office of the Forum
- E. Corrigan
- C. Crofton, PhD
- G. Hernandez, RN
- S. King, MD
- V. Montgomery
- K. Pearson, RPh, MPH
- R. Siegel
- L. Williams
- Editorial Associates,
- Washington, District of Columbia
- G. Martin
- Fast Word, Dallas, Texas
- Health Systems Research,
- Washington, District of Columbia
- MedStat Systems, Inc.,
- Ann Arbor, Michigan
- Mikalix & Company,
- Waltham, Massachusetts
- M. Madison, MPA, and staff
- Moshman and Associates,
- Bethesda, Maryland
- National Institute of Mental Health,
- Bethesda, Maryland
- F. Goodwin, MD, Director
- J. Burke, MD, MPH
- J. Gonzales, MD
- A. Leshner, PhD
- G. Norquist, MD, MSPH
- National Library of Medicine,
- Bethesda, Maryland
- I. Auston, MLS, and staff
- University of California at Los Angeles, California
- D. Schriger, MD, MPH
- University of California at Berkeley, California
- T.W. Hu, PhD
- University of Pittsburgh Medical Center,
- Pittsburgh, Pennsylvania
- M. McDonald, MFA
- Washington Consulting Group, Inc.,
- Washington, District of Columbia
- C.L. Smith