# Acronyms

- AHCPR
- Agency for Health Care Policy and Research
- BDI
- Beck Depression Inventory
- BRDS
- Bech-Rafaelsen Depression Scale
- CDC
- Centers for Disease Control
- CES-D
- Center for Epidemiological Studies--Depression Scale
- DIS
- Diagnostic Interview Schedule
- DNOS
- Depression not otherwise specified
- DSM-III-R
- Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised
- ECA
- Epidemiologic Catchment Area
- ECT
- Electroconvulsive therapy
- GHQ
- General Health Questionnaire
- HRS-D
- Hamilton Rating Scale for Depression
- ICD-9
- International Classification of Diseases, Ninth Edition
- IDDM
- Insulin-dependent diabetes mellitus
- IDS-C
- Inventory for Depression Symptomatology--Clinician Rated
- MADRS
- Montgomery-Asberg Depression Rating Scale
- MAOI
- Monoamine oxidase inhibitor
- MMPI
- Minnesota Multiphasic Personality Inventory
- NIDDM
- Non-insulin-dependent diabetes mellitus
- NIMH
- National Institute of Mental Health
- OCD
- Obsessive-compulsive disorder
- PSE
- Present State Examination
- RDC
- Research Diagnostic Criteria
- SADS
- Schedule for Affective Disorders and Schizophrenia
- SADS-L
- Schedule for Affective Disorders and Schizophrenia--Lifetime Version
- SCL
- Symptom Checklist
- SSRI
- Selective serotonin reuptake inhibitor
- TCA
- Tricyclic antidepressant
- WHO
- World Health Organization
- ZSRDS
- Zung Self-Rating Depression Scale