# References

Akiskal HS. Dysthymic disorder: psychopathology of proposed chronic depressive subtypes. Am J Psychiatry 1983;140:11-20.
Akiskal HS, Khani MK, Scott-Strauss A. Cyclothymic temperamental disorders. Psychiatr Clin North Am 1979;2:527-54.
Alfici S, Sigal M, Landau M. Primary fibromyalgia syndrome--a variant of depressive disorder? Psychother Psychosom 1989;51(3):156-61.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. Washington, DC: American Psychiatric Press; 1980.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. rev. Washington, DC: American Psychiatric Press; 1987.
Angst J, Dobler-Mikola A. The Zurich study: VI. A continuum from depression to anxiety disorders? Eur Arch Psychiatry Neurol Sci 1985;235(3):179-86.
Angst J, Merikangas K, Scheidegger P, Wicki W. Recurrent brief depression: a new subtype of affective disorder. J Affect Disord 1990;19:87-98.
Ballenger JC, Post RM. Carbamazepine in manic-depressive illness: a new treatment. Am J Psychiatry 1980;137:782-90.
Bant WP. Antihypertensive drugs and depression: a reappraisal. Psychol Med 1978;8:275-83.
Barrett JE, Barrett JA, Oxman TE, Gerber PD. The prevalence of psychiatric disorders in a primary care practice. Arch Gen Psychiatry 1988;45:1100-6.
Bartels D, Glasser M, Wang A, Swanson P. Association between depression and propranolol use in ambulatory patients. Clin Pharm 1988;7(2):146-50.
Bauer MS, Whybrow PC. Rapid cycling as a modifier for bipolar disorder. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Bech P, Kastrup M, Rafaelsen OJ. Mini-compendium of rating scales for anxiety, depression, mania, schizophrenia with corresponding DSM-III syndromes. Acta Psychiatr Scand 1986;73:1-39.
Beckham EE, Leber WR. Handbook of depression: treatment, assessment, and research. Homewood, IL: Dorsey Press; 1985.
Bielski RJ, Friedel RO. Prediction of tricyclic antidepressant response: a critical review. Arch Gen Psychiatry 1976;33:1479-89.
Biglan A, Toobert D, Farmer R, Wilson W, Campbell D. Depression among persons with type II diabetes mellitus; unpublished manuscript.
Black DW, Bell S, Hulbert J, Nasrallah A. The importance of axis II in patients with major depression: a controlled study. J Affect Disord 1988;14(2):115-22.
Blacker CVR, Clare AW. The prevalence and treatment of depression in general practice. Psychopharmacology 1988;95:514-7.
Blazer DG. Depression in later life. St. Louis: Mosby-YearBook; 1993.
Blumenthal JA, Williams RS, Wallace AG, Williams RB Jr, Needles TL. Physiological and psychological variables predict compliance to prescribed exercise therapy in patients recovering from myocardial infarction. Psychosom Med 1982;44(6):519-27.
Boyd JH, Burke JD Jr, Gruenberg E, Holzer CE 3rd, Rae DS, George LK, Karno M, Stoltzman R, McEvoy L, Nestadt G. Exclusion criteria of DSM-III: a study of co-occurrence of hierarchy-free syndromes. Arch Gen Psychiatry 1984;41(10):983-9.
Breier A, Charney DS, Heninger GR. The diagnostic validity of anxiety disorders and their relationship to depressive illness. Am J Psychiatry 1985;142(7):787-97.
Bridges KW, Goldberg DP. Somatic presentation of DSM-III psychiatric disorders in primary care. J Psychosom Res 1985;29(6):563-9.
Broadhead WE, Blazer DG, George LK, Tse CK. Depression, disability days, and days lost from work in a prospective epidemiologic survey. JAMA 1990; 264(19):2524-8.
Brown SA, Schuckit MA. Changes in depression among abstinent alcoholics. J Stud Alcohol 1988;49(5):412-7.
Bukberg J, Penman D, Holland JC. Depression in hospitalized cancer patients. Psychosom Med 1984;46:199-212.
Burnam A, Wells K, Rogers W, Potts M. Prevalence of depression in general medical and mental health outpatient practices in three health care systems. Paper presented at: American Psychiatric Association Annual Meeting; 1989 May; San Francisco.
Carney MWP, Roth M, Garside RF. The diagnosis of depressive syndromes and prediction of ECT response. Br J Psychiatry 1965;111:659-74.
Carney RM, Rich MW, teVelde A, Saini J, Clark K, Freedland KE. Prevalence of major depressive disorder in patients receiving beta-blocker therapy versus other medications. Am J Med 1987;83(2):223-6.
Carney RM, Rich MW, Freedland KE, Saini J, teVelde A, Simeone C, Clark K. Major depressive disorder predicts cardiac events in patients with coronary artery disease. Psychosom Med 1988;50:627-33.
Charney DS, Nelson JC, Quinlan DM. Personality traits and disorder in depression. Am J Psychiatry 1981;138(12):1601-4.
Clayton PJ. Mortality and morbidity in the first year of widowhood. Arch Gen Psychiatry 1974;30(6):747-50.
Coryell W, Endicott J, Andreasen NC, Keller MB, Clayton PJ, Hirschfeld RM, Scheftner WA, Winokur G. Depression and panic attacks: the significance of overlap as reflected in follow-up and family study data. Am J Psychiatry 1988;145(3):293-300.
Coryell WR, Noyes R, Clancy J. Excess mortality in panic disorder: a comparison with primary unipolar depression. Arch Gen Psychiatry 1982;39:701-3.
Coryell W, Noyes R, Clancy J. Panic disorder and primary unipolar depression: a comparison of background and outcome. J Affect Disord 1983;5(4):311-7.
Coulehan JL, Schulberg HC, Block MR. The efficiency of depression questionnaires for case finding in primary medical care. J Gen Intern Med 1989;4:542-7.
Coulehan JL, Schulberg HC, Block MR, Janosky JE, Arena VC. Medical comorbidity of major depressive disorder in a primary medical practice. Arch Intern Med 1990;150:2363-7.
Dean C, Kendell RE. The symptomatology of postpartum illness. Br J Psychiatry 1981;139:128-33.
Depression Guideline Panel. Depression in primary care: detection, diagnosis, and treatment. Technical report. Number 5. Rockville, MD: US Department of Health and Human Services, Public Health Service; forthcoming.
Derby IM. Manic-depressive "exhaustion" deaths. Psychiatry Q 1933;7:436.
Deykin EY, Levy JC, Wells V. Adolescent depression, alcohol and drug abuse. Am J Public Health 1987;77(2):178-82.
Dobson KS. An analysis of anxiety and depression scales. J Pers Assess 1985;49(5):522-7.
Dolan JG, Mushlin AI. Routine laboratory testing for medical disorders in psychiatric inpatients. Arch Intern Med 1985;145:2085-8.
Donnelly ER, Murphy DL, Goodwin RK. Cross-sectional and longitudinal comparisons of bipolar and unipolar depressed groups on the MMPI. J Consult Clin Psychol 1976;44:233-7.
Dorus W, Kennedy J, Gibbons RD, Ravi SD. Symptoms and diagnosis of depression in alcoholics. Alcoholism: Clin Exp Res 1987;11(2):150-4.
Drake J, Miller D, Evans R. Cost-effectiveness of thyroid function tests. Arch Intern Med 1982;142:1810-2.
Dworkin SF, von Korff M, LeResche L. Multiple pains and psychiatric disturbance. Arch Gen Psychiatry 1990;47:239-44.
Eastwood MR, Rifat SL, Nobbs H, Ruderman J. Mood disorder following cerebrovascular accident. Br J Psychiatry 1989;154:195-200.
Eaton WW, Holzer CE III, von Korff M, Anthony JC, Helzer JE, George L, Burnam MA, Boyd JH, Kessler LG, Locke BZ. The design of the Epidemiologic Catchment Area surveys. Arch Gen Psychiatry 1984;41:942-8.
Eaton WW, Regier DA, Locke BZ, Taube CA. The Epidemiologic Catchment Area Program of the National Institute of Mental Health. Public Health Rep 1981;96:319-25.
Ebrahim S, Barer KD, Nouri F. Affective illness after stroke. Br J Psychiatry 1987;151:52-6.
Eden S, Sundbeck G, Lindstedt G, Lundberg P-A, Jagenburg R, Landahl S, Svanborg A. Screening for thyroid disease in the elderly. Serum concentrations of thyrotropin and 3,5,3'-triiodothyronine in a representative population of 79-year-old women and men. Compr Gerontol A 1988;2:40-5.
Endicott J. Measurement of depression in patients with cancer. Cancer 1984;53 Suppl:2243-9.
Endicott J, Spitzer RL. A diagnostic interview: the Schedule for Affective Disorders and Schizophrenia. Arch Gen Psychiatry 1978;35:837-44.
Falk WE, Mahnke MW, Poskanzer DC. Lithium prophylaxis of corticotropin-induced psychosis. JAMA 1979;241:1011-2.
Feldman E, Mayou R, Hawton K, Ardern M, Smith EBO. Psychiatric disorder in medical inpatients. Q J Med 1987;63:405-12.
Ferguson B, Dudleston K. Detection of physical disorder in newly admitted psychiatric patients. Acta Psychiatr Scand 1986;74:485-9.
Fishbain DA, Goldberg M, Meagher BR, Steele R, Rosomoff H. Male and female chronic pain patients categorized by DSM-III psychiatric diagnostic criteria. Pain 1986;26:181-97.
Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Fredman L, Weissman MM, Leaf PJ, Bruce ML. Social functioning in community residents with depression and other psychiatric disorders: results of the New Haven Epidemiologic Catchment Area study. J Affect Disord 1988;15:103-12.
Fris R, Friis R, Nanjundappa G. Diabetes, depression and employment status. Soc Sci Med 1986;23:471-5.
Geringer ES, Perlmuter LC, Stern TA, Nathan DM.1986;
Giles DE, Jarrett RB, Biggs MM, Guzick DS, Rush AJ. Clinical predictors of recurrence in depression. Am J Psychiatry 1989;146:764-7.
Goldstein B, Mushlin A. Use of a single thyroxine test to evaluate ambulatory medical patients for suspected hypothyroidism. J Gen Intern Med 1987;2:20-4.
Goodwin DW, Schulsinger F, Hermansen L, Hermansen L, Guze SB, Winokur G. Alcohol problems in adoptees raised apart from alcoholic biological parents. Arch Gen Psychiatry 1973;28:238-43.
Goodwin DW, Schulsinger F, Knopf J, Mednick S, Guze SB. Psychopathology in adopted and nonadopted daughters of alcoholics. Arch Gen Psychiatry 1977;34:1005-9.
Goodwin FK, Bunney WE Jr. Depressions following reserpine: a reevaluation. Sem Psychiatry 1971;3(4):435-48.
Goodwin FK, Jamison KR. Manic-depressive illness. New York: Oxford University Press; 1990.
Grof P, Angst J, Haines T. The clinical course of depression: practical issues. In: Schattauer FK, editor. Classification and prediction of outcomes of depression. Stuttgart: Springer-Verlag; 1974. p. 141-8.
Grundy PF, Roberts CJ. Observations on the epidemiology of post partum mental illness. Psychol Med 1975;5:286-90.
Guiry E, Conroy RM, Hickey N, Mulcahy R. Psychological response to an acute coronary event and its effect on subsequent rehabilitation and lifestyle change. Clin Cardiol 1987;10:256-60.
Gullick EL, King LJ. Appropriateness of drugs prescribed by primary care physicians for depressed outpatients. J Affect Disord 1979;1(1):55-8.
Haley WE, Turner JA, Romano JM. Depression in chronic pain patients: relation to pain, activity, and sex differences. Pain 1985;23:337-43.
Hall RCW, Gardner ER, Stickney SK, LeCann AF, Popkin MK. Physical illness manifesting as psychiatric disease: II. Analysis of a state hospital inpatient population. Arch Gen Psychiatry 1980;37:989-95.
Hall RC, Popkin MK, Kirkpatrick B. Tricyclic exacerbation of steroid psychosis. J Nerv Ment Dis 1978;166(10):738-42.
Hamilton M. Development of a rating scale for primary depressive illness. Br J Soc Clin Psychol 1968;6:278-96.
Hasin DS, Grant BF, Endicott J. Lifetime psychiatric comorbidity in hospitalized alcoholics: subject and familial correlates. Int J Addict 1988;23(8):827-50.
Hecht H, von Zerssen D, Wittchen H. Anxiety and depression in a community sample: the influence of comorbidity on social functioning. J Affect Disord 1990;18:137-44.
Helzer JE, Pryzbeck TR. The co-occurrence of alcoholism with other psychiatric disorders in the general population and its impact on treatment. J Stud Alcohol 1988;49(3):219-24.
Hemphill RE. Incidence and nature of puerperal psychiatric illness. Br Med J 1952;2:1232-5.
Herzberg B, Coppen A. Changes in psychological symptoms in women taking oral contraceptives. Br J Psychiatry 1970;116:161-3.
Herzberg B, Johnson AL, Brown S. Depressive symptoms and oral contraceptives. Br Med J 1970;4:142-5.
Hickie I, Lloyd A, Wakefield D, Parker G. The psychiatric status of patients with the chronic fatigue syndrome. Br J Psychiatry 1990;156:534-40.
Hodkinson H, Denham M. Thyroid function tests in the elderly in the community. Age Ageing 1977;6:67-70.
Hoeper EW, Nycz GR, Cleary PD, Regier DA, Goldberg ID. Estimated prevalence of RDC mental disorder in primary medical care. Int J Ment Health 1979;8:6-15.
Hoppe SK, Leon RL, Realini JP. Depression and anxiety among Mexican Americans in a family health center. Soc Psychiatry Psychiatr Epidemiol 1989;24:63-8.
House A, Dennis M, Magridge L, Warlow C, Hawton K, Jones L. Mood disorders in the year after first stroke. Br J Psychiatry 1991;158:83-92.
Hudson JI, Hudson MS, Pliner LF, Goldenberg DL, Pope HG Jr. Fibromyalgia and major affective disorder: a controlled phenomenology and family history study. Am J Psychiatry 1985;142(4):441-6.
Hughes PL, Wells LA, Cunningham CJ, Ilstrup DM. Treating bulimia with desipramine: a double-blind placebo-controlled study. Arch Gen Psychiatry 1986;43:182-6.
Ionescu R, Popescu C. Personality disorders in students with depressive pathology. Neurol Psychiatr (Bucur) 1989;27:45-55.
Joffe RT, Regan JJ. Personality and depression. J Psychiatr Res 1988;22:279-86.
Johnson D. Study of the use of antidepressant medication in general practice. Br J Psychiatry 1974;125:186-212.
Johnson J, Weissman MM. ECA data reanalysis: a review commissioned by the Panel on Depression, Agency for Health Care Policy and Research, Public Health Service, US Department of Health and Human Services; unpublished manuscript.
Johnson J, Weissman MM, Klerman GL. Panic disorder, comorbidity, and suicide attempts. Arch Gen Psychiatry 1990;47(9):805-8.
Kasper S, Wehr TA, Bartko JJ, Gaist PA, Rosenthal NE. Epidemiological findings of seasonal changes in mood and behavior. Arch Gen Psychiatry 1989;46:823-33.
Kathol R, Mutgi A, Williams J, Clamon G, Noyes R Jr. Diagnosis of major depression in cancer patients according to four sets of criteria. Am J Psychiatry 1990;147:1021-4.
Katon W. The epidemiology of depression in medical care. Int J Psychiatry Med 1987;17(1):93-112.
Katon W. Depression: somatization and social factors. J Fam Pract 1988;27(6):579-80.
Katon W, Kleinman A, Rosen G. Depression and somatization: a review. Part I. Am J Med 1982;72(1):127-35.
Katon W, Ries RK, Kleinman A. Part III: a prospective DSM-III study of 100 consecutive somatization patients. Compr Psychiatry 1984;25:305-14.
Katon W, Vitaliano P, Russo J, Cormier L, Anderson K, Jones M. Panic disorder: epidemiology in primary care. J Fam Pract 1986;23:233-9.
Katon W, von Korff M, Lin E, Lipscomb P, Russo J, Wagner E, Polk E. Distressed high utilizers of medical care: DSM-III-R diagnoses and treatment needs. Gen Hosp Psychiatry 1990;12:355-62.
Kellet JM. Compliance and clinical trials in heart disease [letter]. Lancet 1990;336:1003.
Kendell RE. Invited review. Emotional and physical factors in the genesis of puerperal mental disorders. J Psychosom Res 1985;29:3-11.
Kendell RE, Rennie D, Clarke JA, Dean C. The social and obstetric correlates of psychiatric morbidity. Psychol Med 1981;11:341-50.
Kessler LG, Cleary PD, Burke JD. Psychiatric disorders in primary care. Arch Gen Psychiatry 1985;42:583-7.
Ketai R. Family practitioners' knowledge about treatment of depressive illness. JAMA 1976;235(24):2600-3.
Kolman PBR. Predicting the results of routine laboratory tests in elderly psychiatric patients admitted to hospital. J Clin Psychiatry 1985;46:532-4.
Koran LM, Sox HC, Marton KI, Moltgen S, Sox CH, Kraemer HC, Imai K, Kelsey TG, Rose TG Jr, Levin LC, et al. Medical evaluation of psychiatric patients: I. Results in a state mental health system. Arch Gen Psychiatry 1989;46:733-40.
Korvin CC, Pearce RH, Stanley J. Admission screening: clinical benefits. Ann Intern Med 1975;83:197-203.
Kramlinger KG, Swanson DW, Maruta T. Are patients with chronic pain depressed? Am J Psychiatry 1983;140(6):747-9.
Kroenke K, Wood DR, Mangelsdorff AD, Meier NJ, Powell JB. Chronic fatigue in primary care: prevalence, patient characteristics, and outcome. JAMA 1988;260(7):929-34.
Kruesi MJ, Dale J, Straus SE. Psychiatric diagnoses in patients who have chronic fatigue syndrome [published erratum appears in J Clin Psychiatry 1989;50(4):148]. J Clin Psychiatry 1989;50(2):53-6.
Kupfer DJ, Frank E, Perel JM. The advantage of early treatment intervention in recurrent depression. Arch Gen Psychiatry 1989;46:771-5.
Lalive-Aubert J, Rush AJ. Schizoaffective disorder: a review for DSM-IV. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Lalive-Aubert J, Rush AJ. Toward a DSM-IV classification of schizo-affective (SA) disorder. In: Ferrero FP, Haynal AE, Sartorius N, editors. Schizophrenia and affective psychoses: nosology in contemporary psychiatry. Rome: John Libbey; 1992. p. 141-7.
Large RG. DSM-III diagnoses in chronic pain. J Nerv Ment Dis 1986;174(5):295-303.
Lesko L, Massie M, Holland J. Oncology. In: Stoudemire A, Fogel B, editors. Principles of medical psychiatry. Orlando, FL: Grune & Stratton; 1987. p. 495-520.
Lewis CE, Helzer J, Cloninger CR, Croughan J, Whitman BY. Psychiatric diagnostic predispositions to alcoholism. Compr Psychiatry 1982;23(5):451-61.
Lewis DA, Smith RE. Steroid-induced psychiatric syndromes: a report of 14 cases and a review of the literature. J Affect Disord 1983;5:319-32.
Lindsay PG, Wyckoff M. The depression-pain syndrome and its response to antidepressants. Psychosomatics 1981;22(7):571-7.
Loosen PT, Dew BW, Prange AJ. Long-term predictors of outcome in abstinent alcoholic men. Am J Psychiatry 1990;147:1662-6.
Lumry AE. Bipolar affective disorder: a clinical genetic study. Unpublished doctoral dissertation. Minneapolis: University of Minnesota; 1978.
Lustman PJ, Griffith LS, Clouse RE. Depression in adults with diabetes: results of 5-year follow-up study. Diabetes Care 1988;11:605-12.
Lustman PJ, Griffith LS, Clouse RE, Cryer PE. Psychiatric illness in diabetes: relationship to symptoms and glucose control. J Nerv Ment Dis 1986;174:736-42.
Magni G, Schifano F, de Leo D. Pain as a symptom in elderly depressed patients: relationship to diagnostic subgroups. Arch Psychiatr Neurol Sci 1985;235(3):143-5.
Magruder-Habib K, Zung WWK, Feussner JR, Alling WC, Saunders WB, Stevens HA. Management of general medical patients with symptoms of depression. Gen Hosp Psychiatry 1989;11:201-6.
Manu P, Lane TJ, Matthews DA. The frequency of the chronic fatigue syndrome in patients with persistent fatigue [published erratum appears in Ann Intern Med 1988;109(12):997]. Ann Intern Med 1988;109(7):554-6.
Manu P, Matthews DA, Lane TJ. The mental health of patients with a chief complaint of chronic fatigue: a prospective evaluation and followup. Arch Intern Med 1988;148(10):2213-7.
Marsella J, Hirschfeld R, Katz M. The measurement of depression. New York: Guilford Press; 1987.
Maruta T, Vatterott MK, McHardy MJ. Pain management as an antidepressant: long-term resolution of pain-associated depression. Pain 1989;36:335-7.
Massie MJ, Holland JC. Depression and the cancer patient. J Clin Psychiatry 1990;51(7 Suppl):12-9.
Meltzer ES, Kumar R. Puerperal mental illness, clinical features and classification: a study of 142 mother-and-baby admissions. Br J Psychiatry 1985;147:647-54.
Merikangas KR, Ernst C, Maier W, Hoyer EB, Angst J. Minor depression: prospects for DSM-IV. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Merikangas KR, Hoyer EB, Angst J. Recurrent brief depression: prospects for DSM-IV. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Mindham RH, Marsden LD, Parkes JD. Psychiatric symptoms during L-dopa therapy for Parkinson's disease and their relationship to physical disability. Psychol Med 1976;6:23-33.
Mitchell JE, Groat R. A placebo-controlled, double-blind trial of amitriptyline in bulimia. J Clin Psychopharmacol 1984;4:186-93.
Montague RB, Eaton WW, Larson DB, Mengel MC, Mengel LS, Campbell R. Depressive symptomatology in an IDDM treatment population. Johns Hopkins University, 1990.
Montgomery SA, Asberg M. A new depression scale designed to be sensitive to change. Br J Psychiatry 1979;134:382-9.
Morris PLP, Robinson RG, Raphael B. Prevalence and course of post-stroke depression in hospitalized patients. Int J Psychiatry Med 1990;20:327-42.
Munjack DJ, Moss HB. Affective disorder and alcoholism. Arch Gen Psychiatry 1981;38:869-71.
NIMH Consensus Development Conference Statement. Mood disorders: pharmacologic prevention of recurrences. Am J Psychiatry 1985;142:469-76.
Nott PN. Psychiatric illness following childbirth in Southampton: a case register study. Psychol Med 1982;12:557-61.
Nuutila P, Irjala K, Viikari J, Prinssi VP, Kaihola HL. Comparative evaluation of serum thyroxine, free thyroxine, and thyrotropin determinations in screening of thyroid function. Ann Clin Res 1988;20:158-63.
O'Hara MW, Neunaber DJ, Zekoski EM. Prospective study of postpartum depression: prevalence, course, and predictive factors. J Abnorm Psychol 1984;93:158-71.
O'Sullivan K, Rynne C, Miller J, O'Sullivan S, Fitzpatrick V, Hux M, Cooney J, Clare A. A follow-up study of alcoholics with and without coexisting affective disorder. Br J Psychiatry 1988;152:813-9.
Ormel J, Van Den Brink W, Koeter MWJ, Giel R, Van Der Meer K, Van De Willige G, Wilmink FW. Recognition, management, and outcome of psychological disorders in primary care: a naturalistic follow-up study. Psychol Med 1990;20:909-23.
Paffenbarger RS. Epidemiological aspects of parapartum mental illness. Br J Prev Soc Med 1964;18:189-95.
Paffenbarger RS, McCabe LJ. The effect of obstetric and perinatal events on risk of mental illness in women of childbearing age. PPJH 1966;56:400-7.
Paffenbarger RS, Steinmetz CH, Pooler BG, Hyde RT. The picture puzzle of the postpartum psychoses. J Chronic Dis 1961;13:161-73.
Paykel ES, Fleminger R, Watson JP. Psychiatric effects of antihypertensive drugs other than reserpine. J Clin Psychopharmacol 1982;2(1):14-39.
Petty F. The depressed alcoholic: clinical features and medical management. Gen Hosp Psychiatry 1992;14:458-64.
Pfohl B, Stangl D, Zimmerman M. The implications of DSM-III personality disorders for patients with major depression. J Affect Disord 1984;7:309-18.
Pope HG, Jonas JM, Hudson JI, Cohen BM, Gunderson JG. The validity of DSM-III borderline personality disorder: a phenomenologic, family history, treatment response, and long-term follow-up study. Arch Gen Psychiatry 1983;30:23-30.
Pope HG Jr, Hudson JI, Jonas JM, Yurgelun-Todd D. Bulimia treated with imipramine: a placebo-controlled, double-blind study. Am J Psychiatry 1983;140:554-8.
Pope HG, Katz DL. Affective and psychotic symptoms associated with anabolic steroid use. Am J Psychiatry 1988;145(4):487-90.
Popkin MK. "Secondary" syndromes in DSM-IV: a review of the literature. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Popkin MK, Callies AL. Psychiatric consultation to inpatients with early onset type I diabetes mellitus in a university hospital. Arch Gen Psychiatry 1987; 44:169-71.
Popkin MK, Callies AL, Lentz RD, Colon EA, Sutherland DE. Prevalence of major depression, simple phobia, and other psychiatric disorders in patients with long-standing type 1 diabetes mellitus. Arch Gen Psychiatry 1988;45:64-8.
Post RM. Transduction of psychosocial stress into the neurobiology of recurrent affective disorder. Am J Psychiatry 1992;149(8):999-1010.
Powell BJ, Read MR, Penick EC, Miller NS, Bingham SF. Primary and secondary depression in alcoholic men: an important distinction? J Clin Psychiatry 1987;48(3):98-101.
Purdy D, Frank E. Should postpartum mood disorders be given a more prominent or distinct place in DSM-IV? In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Regier DA, Boyd JH, Burke JD Jr, Rae DS, Myers JK, Kramer M, Robins LN, George LK, Karno M, Locke BZ. One-month prevalence of mental disorders in the United States: based on five Epidemiologic Catchment Area sites. Arch Gen Psychiatry 1988;45:977-86.
Regier DA, Hirschfeld MA, Goodwin FK, Burke JD, Lazar JB, Judd L. The NIMH depression awareness, recognition and treatment program: structure, aims and scientific basis. Am J Psychiatry 1988;145:1351-7.
Regier DA, Myers JK, Kramer M, Robins LN, Blazer DG, Hough RL, Eaton WW, Locke BZ. The NIMH Epidemiologic Catchment Area Program: historical context, major objectives, and study population characteristics. Arch Gen Psychiatry 1984;41:934-41.
Robertson MM, Trimble MR, Townsend HR. Phenomenology of depression in epilepsy. Epilepsia 1987;28:364-72.
Robins E, Gentry KA, Munoz RA, Marten S. A contrast of the three more common illnesses with the ten less common in a study and 18-month follow-up of 314 psychiatric emergency room patients. Arch Gen Psychiatry 1977;34:269-81.
Robins LN, Helzer JE, Weissman MM, Orvaschel H, Gruenberg E, Burke JD, Regier DA. Lifetime prevalence of specific psychiatric disorders in three sites. Arch Gen Psychiatry 1984;41:949-58.
Robinson N, Fuller JH, Edmeades SP. Depression and diabetes. Diabetic Med 1988;5:268-74.
Robinson RG, Bolduc P, Price TR. A two year longitudinal study of post-stroke depression: diagnosis and outcome at one and two year follow-up. Stroke 1987;18:837-43.
Robinson RG, Starr LB, Kubos KL, Price TR. A two year longitudinal study of post-stroke mood disorders: findings during the initial evaluation. Stroke 1983;14:736-44.
Roca RP, Breakey WR, Fischer PJ. Medical care of chronic psychiatric outpatients. Hosp Comm Psychiatry 1987;38:741-5.
Rosen LN, Targum SD, Terman M, Bryant MJ, Hoffman H, Kasper SF, Hamovit JR, Docherty JP, Welch B, Rosenthal NE. Prevalence of seasonal affective disorder at four latitudes. Psychiatry Res 1990;31:131-44.
Rosenthal NE, Levendosky AA, Skwerer RG, Joseph-Vanderpool JR, Kelly KA, Hardin T, Kasper S, DePlabela P, Wehr TA. Effects of light treatment on core body temperature in seasonal affective disorder. Biol Psychiatry 1990;27:39-50.
Ross ED, Rush AJ. Diagnosis and neuroanatomical correlates of depression in brain-damaged patients: implications for a neurology of depression. Arch Gen Psychiatry 1981;38:1344-54.
Rounsaville BJ, Dolinsky ZS, Babor TF, Meyer RE. Psychopathology as a predictor of treatment outcome in alcoholics. Arch Gen Psychiatry 1987; 44:505-13.
Rovner BW, German PS, Brant LJ, Clark R, Burton L, Folstein MF. Depression and mortality in nursing homes. JAMA 1991;265(8):993-6.
Rush AJ, Cain JW, Raese J, Stewart RS, Waller DA, Debus JD. Neurobiological bases for psychiatric disorders. In: Rosenberg RN, editor. Comprehensive neurology. New York: Raven Press; 1991. p. 555-603.
Rush AJ, Giles DE, Schlesser MA, Fulton CL, Weissenburger J, Burns C. The inventory for depressive symptomatology (IDS): preliminary findings. Psychiatry Res 1986;18:65-87.
Rush AJ, Hollon S, Beck AT, Kovacs M. Depression: must pharmacotherapy fail for cognitive therapy to succeed? Cognitive Ther Res 1978;2:199-206.
Rush AJ, Weissenburger J. Melancholic symptom features: a review for DSM-IV. In: Frances AJ, Widiger T. editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Sargeant JK, Bruce ML, Florio LP, Weissman MM. Factors associated with 1-year outcome of major depression in the community. Arch Gen Psychiatry 1990;47:519-26.
Schaffer CB, Donlon PT, Bittle RM. Chronic pain and depression: a clinical and family history survey. Am J Psychiatry 1980;137(1):118-20.
Schatzberg AF, Rothschild AJ. Psychotic (delusional) major depression: issues for DSM-IV. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Schatzberg AF, Rothschild AJ. Psychotic (delusional) major depression: should it be included as a distinct syndrome? Am J Psychiatry 1992;149:733-45.
Schleifer SJ, Macari-Hinson MM, Coyle DA, Slater WR, Kahn M, Gorlin R, Zucker HD. The nature and course of depression following myocardial infarction. Arch Intern Med 1989;149:1785-9.
Schuckit MA. Alcoholic men with no alcoholic first-degree relatives. Am J Psychiatry 1983;140(4):439-43.
Schuckit MA. Genetics and the risk for alcoholism. JAMA 1985;254:2614-7.
Schuckit MA. The relationship between alcohol problems, substance abuse, and psychiatric syndromes. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Schulberg HC, Saul M, McClelland M, Ganguli M, Christy W, Frank R. Assessing depression in primary medical and psychiatric practices. Arch Gen Psychiatry 1985;42:1164-70.
Shea MT, Glass DR, Pilkonis PA, Watkins J, Docherty JP. Frequency and implications of personality disorders in a sample of depressed outpatients. J Pers Disord 1987;1:27-42.
Silver RJ, Isaacs K, Mansky P. MMPI correlates of affective disorders. J Clin Psychol 1981;31(4):836-9.
Slap GB. Oral contraceptives and depression: impact, prevalence and cause. J Adolesc Health Care 1981;2:53-64.
Slawson PF, Flynn WR, Kollar EJ. Psychological factors associated with the onset of diabetes mellitus. JAMA 1963;185:166-70.
Sox HC, Koran LM, Sox CH, Marton KI, Dugger F, Smith T. A medical algorithm for detecting physical disease in psychiatric patients. Hosp Comm Psychiatry 1989;40:1270-6.
Strober M, Carlson G. Bipolar illness in adolescents with major depression: clinical, genetic, and psychopharmacologic predictors in a three- to four-year prospective followup investigation. Arch Gen Psychiatry 1982;39:549-55.
Sugarman J, Berg A. Evaluation of fatigue in a family practice. J Fam Pract 1984;5:643-7.
Taylor B, Tomson J, Caird F. Further studies of thyroid function tests in the elderly at home. Age Ageing 1974;3:122-6.
Terman M. On the question of mechanism in phototherapy for seasonal affective disorder: considerations of clinical efficacy and epidemiology. J Biol Rhythms 1988;3:155-72.
Terman M, Botticelli SR, Link B, Link MJ, Hardin T, Rosenthal NE. Seasonal symptom patterns in New York: patients and population. In: Silverstone T, Thompson C, editors. Seasonal affective disorder. London: Clinical Neuroscience Publishers; 1989. p. 77-95.
Thompson LW, Gallagher D, Czirr R. Personality disorder and outcome in the treatment of late-life depression. J Geriatr Psychiatry 1988;21(2):133-46.
Turner JA, Romano JM. Self-report screening measures for depression in chronic pain patients. J Clin Psychol 1984;40(4):909-13.
VA Cooperative Study Group on Antihypertensive Agents. Comparison of propranolol and hydrochlorothiazide for the initial treatment of hypertension. JAMA 1982;248(16):2004-11.
Vollrath M, Koch R, Angst J. The Zurich study: IX. Panic disorder and sporadic panic: symptoms, diagnosis, prevalence, and overlap with depression. Eur Arch Psychiatry Neurol Sci 1990;239:221-30.
von Knorring A-L, Bohman M, von Knorring L, Oreland L. Platelet MAO activity as a biological marker in subgroups of alcoholism. Acta Psychiatr Scand 1985;72:51-8.
von Knorring L, Perris C, Eisemann M, Eriksson U, Perris H. Pain as a symptom in depressive disorders: I. Relationship to diagnostic subgroup and depressive symptomatology. Pain 1983;15:19-26.
von Korff M, Ormel J, Katon W, Lin E. Disability and depression among high utilizers of health care: a longitudinal analysis. Arch Gen Psychiatry 1992;49:91-100.
von Korff M, Shapiro S, Burke JD, Teitlebaum M, Skinner EA, German P, Turner RW, Klein L, Burns B. Anxiety and depression in a primary care clinic. Arch Gen Psychiatry 1987;44:152-6.
Wade DT, Leigh-Smith JE, Heuer RA. Depressed mood after stroke: a community study of its frequency. Br J Psychiatry 1987;151:200-5.
Walker E, Katon A, Harrop-Griffiths J, Holm L, Russo J, Hickok LR. Relationship of chronic pelvic pain to psychiatric diagnoses and childhood sexual abuse. Am J Psychiatry 1988;145(1):75-80.
Walker LS, Greene JW. Children with recurrent abdominal pain and their parents: more somatic complaints, anxiety, and depression than other patient families. J Pediatr Psychol 1989;14(2):231-43.
Walsh BT, Stewart JW, Wright L, Harrison W, Roose SP, Glassman AH. Treatment of bulimia with monoamine oxidase inhibitors. Am J Psychiatry 1982;139(12):1629-30.
Weissman MM, Gershon ES, Kidd KK, Prusoff BA, Leckman JF, Dibble E, Hamovit J, Thompson WD, Pauls DL, Guroff JJ. Psychiatric disorders in the relatives of probands with affective disorders. Arch Gen Psychiatry 1984;41:13-21.
Weissman MM, Johnson J. Epidemiology of dysthymia. Paper presented at: Symposium--dysthymia: is dysthymia an affective disorder? 29th Annual Meeting of the ACNP; 1990 Dec 10-14; San Juan, PR.
Weissman MM, Klerman GL. Epidemiology of mental disorders: emerging trends in the United States. Arch Gen Psychiatry 1978;35:705-12.
Weissman MM, Leaf PJ, Tischler GL, Blazer DG, Karno M, Livingston BM, Florio LP. Affective disorders in five United States communities. Psychol Med 1988;18:141-53.
Weissman MM, Myers JK. Affective disorders in a US urban community: the use of Research Diagnostic Criteria in an epidemiologic study. Arch Gen Psychiatry 1978;35:1304-11.
Weissman MM, Myers JK. Psychiatric disorders in a US urban community: the application of Research Diagnostic Criteria to a resurveyed community sample. Acta Psychiatr Scand 1980;62:99-111.
Weitzler KR, Strauman JJ, Dubro A. Diagnosis of major depression by self-report. J Pers Assess 1989;53(1):22-30.
Weller EB, Weller RA. Depressive disorders in children and adolescents. In: Garfinkel BD, Carlson GA, Weller EB, editors. Psychiatric disorders in children and adolescents. Philadelphia: WB Saunders Company; 1990. p. 3-20.
Wells KB. Depression as a tracer condition for the national study of medical care outcomes--background review. Santa Monica: RAND; 1985.
Wells KB, Golding JM, Burnam MA. Psychiatric disorder and limitations in physical functioning in a sample of the Los Angeles general population. Am J Psychiatry 1988a;145:712-7.
Wells KB, Golding JM, Burnam MA. Psychiatric disorder in a sample of the general population with and without chronic medical conditions. Am J Psychiatry 1988b;145:976-81.
Wells KB, Golding JM, Burnam MA. Affective, substance use, and anxiety disorders in persons with arthritis, diabetes, heart disease, high blood pressure, or chronic lung conditions. Gen Hosp Psychiatry 1989;11:320-7.
Wells KB, Stewart A, Hays RD, Burnam MA, Rogers W, Daniels M, Berry S, Greenfield S, Ware J. The functioning and well-being of depressed patients: results from the Medical Outcomes Study. JAMA 1989;262(7):914-9.
Willenbring ML. Measurement of depression in alcoholics. J Stud Alcohol 1986;47(5):367-72.
Willett AB, King T. Implementation of laboratory screening procedures on a short term psychiatric inpatient unit. Dis Nerv Syst 1977;38:867-70.
Wing J, Birley J, Cooper J, Graham P, Isaacs A. Reliability of a procedure for measuring and classifying "Present Psychiatric State." Br J Psychiatry 1967;113:499-515.
Wing RR, Marcus MD, Blair EH, Epstein LH, Burton LR. Depressive symptomatology in obese adults with type II diabetes. Diabetes Care 1990;13(2):170-2.
Winokur G, Reich T, Rimmer J, Pitts FN Jr. Alcoholism: III. Diagnosis and familial psychiatric illness in 259 alcoholic probands. Arch Gen Psychiatry 1970;23(2):104-11.
Wolfe F, Smythe HA, Yunus MB, Bennett RM, Bombardier C, Goldenberg DL, Tugwell P, Campbell SM, Abeles M, Clark P, et al. The American College of Rheumatology 1990 criteria for the classification of fibromyalgia: report of the Multicenter Criteria Committee. Arthritis Rheum 1990;33(2):160-72.
Woodruff RA, Guze SB, Clayton PJ, Carr D. Alcoholism and depression. Arch Gen Psychiatry 1973;28:97-100.
Zich JM, Attkisson CC, Greenfield TK. Screening for depression in primary care clinics: the CES-D and the BDI. Int J Psychiatry Med 1990;20:259-77.
Zimmerman M, Coryell W. DSM-III personality disorder diagnoses in a nonpatient sample: demographic correlates and comorbidity. Arch Gen Psychiatry 1989;46:682-9.
Zimmerman M, Coryell W, Stangl D, Pfohl B. Validity of an operational definition for neurotic unipolar major depression. J Affect Disord 1987;12:29-40.
Zinbarg RE, Barlow DH, Liebowitz M, Broadhead E, Katon W, Roy-Byrne P, Lepine J, Teherani M, Richards J, Brantly P, Kraemer HC. DSM-IV field trial: mixed anxiety depression. In: Frances AJ, Widiger T, editors. DSM-IV sourcebook. Washington, DC: American Psychiatric Press; in press.
Zisook S, Schuckit MA. Male primary alcoholics with and without family histories of affective disorder. J Stud Alcohol 1987;48(4):337-44.
Zisook S, Shuchter SR. Depression through the first year after the death of a spouse. Am J Psychiatry 1991;148(10):1346-52.