# Executive Summary

Up to one in eight individuals may require treatment for depression during their lifetimes. The direct costs of treatment for major depressive disorder combined with the indirect costs from lost productivity are significant, accounting for approximately $16 billion per year in 1980 dollars. Regrettably, only one-third to one-half of those with major depressive disorder are properly recognized by practitioners. Fewer than one-third of patients with bipolar disorder are in treatment.

Despite the high prevalence of depressive symptoms and major depressive episodes in patients of all ages, depression is underdiagnosed and undertreated by primary care and other nonpsychiatric practitioners, who are, paradoxically, the providers most likely to see these patients initially. Depression may occur concurrently with other nonpsychiatric general medical disorders or with other psychiatric disorders; it may also be brought on by the use of certain medications. Major risk factors for depression include a personal or family history of depressive disorder, prior suicide attempts, female gender, lack of social supports, stressful life events, and current substance abuse. The social stigma surrounding depression is substantial and often prevents the optimal use of current knowledge and treatments. The cost of the illness in pain, suffering, disability, and death is high.

Once identified, depression can almost always be treated successfully, either with medication, psychotherapy, or a combination of both. Not all patients respond to the same therapy, but a patient who fails to respond to the first treatment attempted is highly likely to respond to a different treatment.

This Clinical Practice Guideline focuses on the diagnosis of depressive disorders, particularly in outpatients. Depression is defined according to the current U.S. standard diagnostic system in the Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised (DSM-III-R), published by the American Psychiatric Association.