# Acknowledgments

These guidelines were developed with the help of many dedicated contributors. The reviewing consultants for treatment issues searched and compiled a vast literature. The scientific reviewers critiqued the reviews and several drafts of the guideline document. A variety of professional organizations, patient groups, and individuals provided peer review and pilot-tested the guidelines. Finally, critical administrative, scientific, technical, and secretarial support made the entire effort feasible. A full listing of all those involved in this effort appears in the lists of contributors at the end of this document.

Special recognition goes to David Schriger, MD, MPH, UCLA School of Medicine, Los Angeles, California, panel methodologist, who critiqued all reviews and drafts of the guidelines and helped to conceptualize the overall approach, specify clinical issues, and organize the relevant data. Extraordinary credit also goes to Madhukar Trivedi, MD, Instructor, Department of Psychiatry, University of Texas Southwestern Medical Center, Dallas, Texas, scientific assistant to the chair, who helped to conceptualize the overall approach, conduct all meta-analyses, and review most studies of medication efficacy. Without him, this project would not have been possible.