# Panel Members

- A. John Rush, MD, Chair
- Betty Jo Hay Distinguished Chair in Mental Health
- Professor and Vice Chairman for Research, Department of Psychiatry
- University of Texas
- Southwestern Medical Center
- Dallas, Texas
- Specialty: Psychiatry
- William E. Golden, MD
- Director, General Internal Medicine
- Associate Professor,
- Department of Medicine
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas
- Specialty: General Internal Medicine
- Gladys Walton Hall, PhD, MSW
- Associate Professor,
- School of Social Work
- Howard University
- Washington, District of Columbia
- Specialty: Social Work
- Col. Moses Herrera, MD
- Chief, Primary Care Clinic
- Robins Air Force Base Hospital
- Robins Air Force Base, Georgia
- Specialty: Family Medicine
- Artie Houston
- Consumer Representative
- Fort Worth, Texas
- Roger G. Kathol, MD
- Professor of Psychiatry and Internal Medicine
- University of Iowa Hospitals and Clinics
- Iowa City, Iowa
- Specialty: Psychiatry and Internal Medicine
- Wayne Katon, MD
- Professor of Psychiatry
- Chief of Consultation-Liaison Psychiatry
- University of Washington Medical School
- Seattle, Washington
- Specialty: Psychiatry
- Catherine L. Matchett, MD
- Matchett Medical Center, President
- Grapevine, Texas
- Specialty: Family Medicine
- Frederick Petty, PhD, MD
- Associate Professor,
- Department of Psychiatry
- Veterans Administration Medical Center
- University of Texas
- Southwestern Medical Center
- Dallas, Texas
- Specialty: Psychiatry
- Herbert C. Schulberg, PhD
- Professor of Psychiatry, Psychology and Medicine
- University of Pittsburgh
- School of Medicine
- Pittsburgh, Pennsylvania
- Specialty: Psychology and Community Mental Health
- G. Richard Smith, Jr., MD
- Professor and Director
- Centers for Mental Healthcare Research
- VA HSR & D Field Program for Mental Health
- University of Arkansas for Medical Sciences
- Little Rock, Arkansas
- Specialty: Psychiatry and Health Services Research
- Gail Wiscarz Stuart, PhD, RN, CS
- Associate Professor and Chief,
- Division of Psychiatric Nursing
- Department of Psychiatry and Behavioral Sciences
- Professor, College of Nursing
- Medical University of South Carolina
- Charleston, South Carolina
- Specialty: Psychiatric Nursing