# Contributors [1]

## Methodology Consultants

[1] Being listed as a contributor does not necessarily imply endorsement of the guideline.

- Kay Dickersin, PhD
- University of Maryland School of Medicine
- Baltimore, Maryland
- Earl P. Steinberg, MD, MPP
- The Johns Hopkins School of Medicine
- Baltimore, Maryland

## Consultants, Contributors, Peer Reviewers, and Pilot Reviewers

- Richard L. Abbott, MD
- Clinical Professor
- Department of Ophthalmology
- California Pacific Medical Center
- San Francisco, California
- Ingrid Adamsons, MD, MPH
- Wilmer Eye Institute
- The Johns Hopkins School of Medicine
- Baltimore, Maryland
- Paul C. Ajamian, OD, FAAO
- Omni Eye Services of Atlanta
- Atlanta, Georgia
- Raymond A. Applegate, OD, PhD
- Department of Ophthalmology
- University of Texas Health Science Center at San Antonio
- San Antonio, Texas
- James V. Aquavella, MD
- University of Rochester Medical Center
- Rochester, New York
- Ian L. Bailey, OD
- School of Optometry
- University of California, Berkeley
- Berkeley, California
- Hal D. Balyeat, MD
- Dean A. McGee Eye Institute
- Oklahoma City, Oklahoma
- Ray M. Balyeat, MD
- Eye Institute of Tulsa
- Clinical Instructor
- University of Oklahoma
- College of Medicine-Tulsa
- Tulsa, Oklahoma
- George M. Bohigian, MD
- Washington University School of Medicine
- St. Louis, Missouri
- William M. Bourne, MD
- Mayo Clinic
- Rochester, Minnesota
- Maureen Brennan-Duggan, RN, BSN, CRNO
- Eye Medical Clinic of Santa Clara Valley
- San Jose, California
- William E. Bruner, MD
- Case Western Reserve University School of Medicine
- Cleveland, Ohio
- Emmett F. Carpel, MD
- Department of Ophthalmology
- University of Minnesota
- Hennepin County Medical Center
- Group Health, Inc.
- Minneapolis, Minnesota
- Chris Carpenter, MSW
- Mid-Maine Medical Center
- Waterville, Maine
- Clark R. Cobble, MD
- Danville Eye Center, Inc.
- Danville, Virginia
- Matthew E. Dangel, MD
- Department of Ophthalmology
- Ohio State University
- Columbus, Ohio
- Gordon H. DeFriese, PhD
- Professor of Social Medicine,
- Epidemiology and Health Policy and Administration
- Director,
- Cecil G. Sheps Center for Health Services Research
- University of North Carolina at Chapel Hill
- Chapel Hill, North Carolina
- Robert C. Drews, MD
- Professor of Clinical Ophthalmology
- Washington University School of Medicine
- St. Louis, Missouri
- David A. Durfee, MD
- Oregon Eye Care
- Oregon City, Oregon
- Peter Egbert, MD
- Stanford University
- Stanford, California
- James H. Elliot, MD
- Professor of Ophthalmology
- Vanderbilt University School of Medicine
- Nashville, Tennessee
- Darrin P. Fleming
- The Turner Eye Institute
- San Leandro, California
- Robert H. Friedman, MD
- The University Hospital
- Boston University Medical Center
- Boston, Massachusetts
- Lea Gamble, BA
- American Academy of Ophthalmology
- San Francisco, California
- Susan C. Garratt, BA
- Freelance Editor
- Mill Valley, California
- Stephen C. Gieser, MD, MPH
- The Johns Hopkins School of Medicine
- Baltimore, Maryland
- Martha S. Gerrity, MD, MPH
- Cecil G. Sheps Center for Health Services Research
- University of North Carolina
- Chapel Hill, North Carolina
- Thomas C. Gettelfinger, MD
- Clinical Associate Professor of Ophthalmology
- University of Tennessee Center for Health Sciences
- Memphis, Tennessee
- Robert J. Glynn, PhD, ScD
- Department of Medicine
- Brigham and Women's Hospital
- Boston, Massachusetts
- Philip M. Gold, MD
- American College of Physicians
- Philadelphia, Pennsylvania
- Kathryn Goldblum, RN, MSN, CRNO
- Albuquerque, New Mexico
- John D. Gottsch, MD
- Associate Professor of Ophthalmology
- Wilmer Eye Institute
- The Johns Hopkins University
- Baltimore, Maryland
- David Hadorn, MD
- RAND Corporation
- Santa Monica, California
- Lisa M. Herdelin, BBA
- Department of Ophthalmology
- Vanderbilt University Medical Center
- Nashville, Tennessee
- Roger Hernandez, MD
- San Antonio, Texas
- Patricia L. Hibbard, MD, PhD
- Harvard Medical School and Massachusetts General Hospital
- Boston, Massachusetts
- Janet E. Huettig, MSW, LICSW
- Massachusetts Eye and Ear Infirmary
- Boston, Massachusetts
- Anthony C. Jaspers, MD, FAAFP
- American Academy of Family Physicians
- Kansas City, Missouri
- Jonathan C. Javitt, MD, MPH
- Georgetown University Medical Center
- Washington, DC
- Karla J. Johns, MD
- Vanderbilt University School of Medicine
- Nashville, Tennessee
- Paul R. Katz, MD
- University of Rochester School of Medicine and Dentistry
- Rochester, New York
- Robert H. Kennedy, MD, MPH
- University of Texas Southwestern Medical Center
- Dallas, Texas
- Joanne Klopfer, OD, MPH
- Dana Center for Preventive Ophthalmology
- Wilmer Eye Institute
- The Johns Hopkins University Hospital
- Baltimore, Maryland
- Douglas D. Koch, MD
- Cullen Eye Institute
- Baylor College of Medicine
- Houston, Texas
- Manus C. Kraff, MD
- American Academy of Ophthalmology
- Chicago, Illinois
- Stephen S. Lane, MD
- Associate Clinical Professor
- University of Minnesota
- Minneapolis, Minnesota
- Roger H. S. Langston, MD, CM, FACS
- Cleveland Clinic Foundation
- Cleveland, Ohio
- Thomas L. Lewis, OD, PhD
- Pennsylvania College of Optometry
- Philadelphia, Pennsylvania
- Thomas J. Liesegang, MD
- Mayo Clinic Jacksonville
- Jacksonville, Florida
- Wilber W. Linville, OD, FAAO
- Clinical Faculty
- School of Optometry
- University of California, Berkeley
- Berkeley, California
- Rajiv Luthra, MD, MPH
- The Johns Hopkins School of Medicine
- Baltimore, Maryland
- Michael F. Marmor, MD
- Stanford University
- Stanford, California
- James F. Martone, MD, MPH
- ORBIS International
- New York, New York
- Samuel Masket, MD
- Jules Stein Eye Institute
- UCLA School of Medicine
- Los Angeles, California
- R. Michael Massanari, MD, MS
- Henry Ford Medical Center
- Case Western Reserve University
- Detroit, Michigan
- Alice Y. Matoba, MD
- Houston Veterans Affairs Hospital and Baylor College of Medicine
- Houston, Texas
- David Musch, PhD, MPH
- University of Michigan
- Departments of Ophthalmology and Epidemiology
- Ann Arbor, Michigan
- Randall J. Olson, MD
- University of Utah
- School of Medicine
- Salt Lake City, Utah
- Carolyn M. Parrish, MD
- Vanderbilt University School of Medicine
- Nashville, Tennessee
- David F. Partlett, LLB, LLM, JJD
- Vanderbilt University School of Law
- Nashville, Tennessee
- John C. Perlmutter, MD
- Assistant Professor of Clinical Ophthalmology and Visual Sciences
- Washington University School of Medicine
- St. Louis, Missouri
- W. David Pool, OD
- Illinois Optometric Association
- Galva, Illinois
- Neil R. Powe, MD, MPH, MBA
- The Johns Hopkins School of Medicine
- Baltimore, Maryland
- Dinah Reitman, MPS
- Mt. Sinai School of Medicine
- New York, New York
- Claudia U. Richter, MD
- Harvard Medical School
- Boston, Massachusetts
- Bridget Reilly, PhD
- Vanderbilt University
- Nashville, Tennessee
- Gary S. Rubin, PhD
- The Johns Hopkins University School of Medicine
- Baltimore, Maryland
- Henry S. Sacks, PhD, MD
- Mount Sinai School of Medicine
- New York, New York
- Oliver D. Schein, MD, MPH
- The Johns Hopkins University
- Baltimore, Maryland
- Pamela S. Schremp, RN, MSN, CRNO
- University Hospitals of Cleveland
- Case Western Reserve University
- Cleveland, Ohio
- Charles B. Slonim, MD, FACS
- Clinical Assistant Professor
- University of South Florida College of Medicine
- Tampa, Florida
- Carol Standardi, RN, CRNO
- W.K. Kellogg Eye Center
- Department of Ophthalmology
- University of Michigan
- Ann Arbor, Michigan
- John A. Stanley, MD
- University of California
- San Francisco, California
- Walter J. Stark, MD
- Wilmer Eye Institute
- The Johns Hopkins Hospital
- Baltimore, Maryland
- Richard H. Stein, MD
- Good Samaritan Hospital
- Vincennes, Indiana
- Gary M. Stephenson, MS
- President,
- MED-WRITE
- Sykesville, Maryland
- Hunter R. Stokes, Sr., MD, FACS
- Acting Chairman and Professor
- Department of Ophthalmology University of South Carolina School of Medicine
- Columbia, South Carolina
- Ellen Strahlman, MD, MHS
- Merck, Sharpe and Dohme Research Laboratories
- Blue Bell, Pennsylvania
- Debra A. Street, MPH
- Worthen Center for Eye Care Research
- Georgetown University Medical Center
- Washington, D.C.
- Alan Sugar, MD
- Kellogg Eye Center
- University of Michigan
- Ann Arbor, Michigan
- Joel Sugar, MD
- University of Illinois at Chicago
- Department of Ophthalmology and Visual Science
- Chicago, Illinois
- Jeffrey Susman, MD
- Vice-Chairperson
- Department of Family Medicine
- University of Nebraska Medical Center
- Omaha, Nebraska
- James M. Tielsch, PhD
- The Johns Hopkins School of Medicine
- Baltimore, Maryland
- Peter S. Visendi, OD, FAAO
- Assistant Clinical Professor
- University of California, Berkeley
- Berkeley, California
- Jonathan P. Weiner, DrPH
- The Johns Hopkins School of Public Health
- Baltimore, Maryland
- Sheila West, PhD
- Associate Professor
- Dana Center, Wilmer Eye Institute,
- The Johns Hopkins University
- Baltimore, Maryland
- Charles E. Womack, MD
- American Academy of Family Physicians
- Oklahoma City, Oklahoma
- Stephen K. Wong, MD
- Specialist: Cataract/Corneal Surgery
- Sacramento, California
- Kenneth Zahl, MD
- Assistant Professor of Clinical Anesthesiology
- Columbia University
- New York, New York

### Agency for Health Care Policy and Research

- Jean R. Slutsky, PA, MSPH
- Lawrence E. Williams
- Margaret K. Rutherford
- Rose Calbert Findley, MUP
- Harriett V. Bennett

### National Library of Medicine

- Ione Auston, MLS

### Contract Agencies

- Health Systems Research, Inc.
- Washington, D.C.
- Mikalix and Company, Inc.
- Waltham, Massachusetts
- Moshman Associates, Inc.
- Bethesda, Maryland
- Washington Consulting Group, Inc.
- Washington, D.C.