# Biosketches

Numerous individuals have contributed their time and efforts to the development of this guideline. Their intense efforts and support during the critical interactive process have been an integral part of the success of this document.

- DENIS M. O'DAY, MD, FACS
- (Panel Chair)
- George Weeks Hale Professor and Chair
- Department of Ophthalmology
- Vanderbilt University School of Medicine

He is an ophthalmologist, the George Weeks Hale Professor of Ophthalmology, and Chairman of the Department of Ophthalmology at the Vanderbilt University School of Medicine in Nashville, Tennessee, and a Director on the American Board of Ophthalmology. He is a founding member and is now Chair of the Quality of Care Committee of the American Academy of Ophthalmology. He has been involved in the development of a series of clinical guidelines for ophthalmology and has authored over 150 articles and book chapters.

- ANTHONY J. ADAMS, OD, PhD
- Dean
- School of Optometry
- University of California

He is a Professor of Optometry at the University of California at Berkeley. He has been Chairman of the National Research Council Committee on Vision and President of the National Board of Optometry. In 1991, he was elected to the Council of the American Academy of Optometry. He has published over 200 papers on various aspects of visual disorders.

- EDWIN H. CASSEM, MD, FACP
- Chief of Psychiatry
- Department of Psychiatry
- Massachusetts General Hospital

He is Chief of Psychiatry at Massachusetts General Hospital, Boston, and an Associate Professor of Psychiatry, Harvard Medical School. A Jesuit priest, he has degrees in experimental psychology, philosophy, and theology. He has specialized for 25 years in psychiatric care of the medically ill and is Chairman of the Optimum Care Committee at Massachusetts General Hospital.

- JOHN V. DONLON, Jr., MD
- Acting Chairman
- Department of Anesthesiology
- Massachusetts Eye and Ear Infirmary

He is Chief of Anesthesia at the Massachusetts Eye and Ear Infirmary, Boston, and Associate Clinical Professor of Anesthesia, Harvard Medical School. He specializes in the clinical practice of anesthesia as it relates to the surgical care of patients with cataract. He has written extensively on this topic.

- DONALD J. DOUGHMAN, MD, FACS
- Professor
- Department of Ophthalmology
- University of Minnesota Hospital and Clinic

He is an ophthalmologist, specializing in the medical and surgical treatment of diseases of the anterior segment of the eye, including cataract. He is a Professor of Ophthalmology at the University of Minnesota in Minneapolis. He is a member of the AHCPR Cataract Patient Outcomes Research Team and has served on national committees involved with quality of care issues.

- DAGMAR B. FRIEDMAN, MPH, LICSW
- Consultant
- Vision Rehabilitation Services
- Massachusetts Eye and Ear Infirmary

She is a clinical social worker with a psychotherapy practice in the Boston area. She currently serves on the Commonwealth of Massachusetts Statutory Advisory Board for the Massachusetts Commission for the Blind. She has extensive experience reviewing, designing, and implementing programs in visual rehabilitation. She has worked with patients with functional impairment due to cataract for many years and has developed a preventive health program for older adults in a large senior citizen center. She also served on the national task force to develop guidelines and standards for low-vision services throughout the United States.

- CATHERINE GLYNN-MILLEY, RN, CRNO
- President
- Specialty Nursing Agency, Inc.

She is a certified ophthalmic registered nurse. Since 1982, she has provided in-home ophthalmic nursing services for patients in Santa Clara County, California. She has extensive experience managing patients following cataract surgery. A quality assurance plan addressing cost effectiveness and efficient community health care issues is the framework for her program. She also coordinates a blindness prevention program for the same community.

- HARRY L. KNOPF, MD
- Associate Professor of Clinical Ophthalmology
- Department of Ophthalmology and Visual Sciences
- Washington University School of Medicine

He is an ophthalmologist in private practice in St. Louis, Missouri. He is an Associate Professor of Clinical Ophthalmology, Washington University School of Medicine, and has served on several peer-review committees, including the National Advisory Committee on Patient Outcomes Assessment Research Program, Cataract Surgery, for the Health Care Financing Administration, and the Anterior Segment panel for the American Academy of Ophthalmology. He has experience in guideline development in these settings.

- ERNEST L. MAZZAFERRI, MD, FACP
- Professor and Chairman
- Department of Internal Medicine
- Ohio State University College of Medicine

He is a practicing internist and Professor and Chairman of the Department of Internal Medicine and Professor of Physiology at Ohio State University. He is also Chairman of Internal Medicine at Ohio State University Hospitals and Clinics. He is the author of over 200 medical and scientific articles, abstracts, and books. He has broad experience writing clinical guidelines as a member of the American College of Physicians' subcommittees in this area.

- STEPHEN A. OBSTBAUM, MD
- Professor of Clinical Ophthalmology
- Cornell University Medical School
- Director
- Department of Ophthalmology
- Lenox Hill Hospital

He is Professor of Clinical Ophthalmology at the Cornell University Medical School and Director of the Department of Ophthalmology at the Lenox Hill Hospital in New York City. He is Past President of the American Society of Cataract and Refractive Surgery and Editor of the Journal of Cataract and Refractive Surgery. He serves on the Board of Directors for the American Academy of Ophthalmology and is a member of the panel for developing the Preferred Practice Pattern on Cataract Surgery.

- CHARLES J. PAPPAS, OD
- Director of Optometric Services
- Bascom Palmer Eye Institute
- University of Miami School of Medicine

He is the Director of Optometric Services at the Bascom Palmer Eye Institute, University of Miami School of Medicine, with academic, clinical, consultative, and administrative responsibilities. He is a member of the Florida and American Optometric Associations.

- EVA N. SKINNER, RN
- Consultant
- Los Angeles, California

She is a public health nurse and has worked in the geriatric field since 1964. She is a member of the Board of Directors of the American Association for Retired Persons and is a board member of the Visiting Nurse Association of America and California Medical Review, Inc., a peer review organization for Medicare in California. She is Chair of the California Commission on Aging.

- ALFRED SOMMER, MD, MHS
- Dean
- The Johns Hopkins University School of Hygiene and Public Health

He is an ophthalmologist, Dean and Professor of Epidemiology at The Johns Hopkins School of Hygiene and Public Health, and a Professor of Ophthalmology at the Wilmer Institute. He was Founding Chair of the American Academy of Ophthalmology's Quality of Care Committee, which published 12 practice guidelines. He is Co-Principal Investigator of the AHCPR Cataract Patient Outcomes Research Team.

- ARLO C. TERRY, MD
- Associate Clinical Professor of Ophthalmology
- University of Texas

He is an ophthalmologist in private practice, specializing in medical and surgical treatment of diseases of the anterior segment of the eye, including cataract. He is also an Associate Professor of Ophthalmology at the University of Texas, San Antonio. A founding member of the American Academy of Ophthalmology Quality of Care Committee, he has been involved in the production of a series of clinical guidelines for ophthalmology, including cataract.

- LINDA A. VADER, RN, CRNO
- Certified Registered Nurse in Ophthalmology
- University of Michigan Kellogg Eye Center

She is a certified registered nurse in ophthalmology, with 15 years experience as Head Nurse at the University of Michigan Kellogg Eye Center. She was Charter President of the National Certifying Board of Ophthalmic Registered Nurses and is the Immediate Past President of the American Society of Ophthalmic Registered Nurses.

- JAMES R. WEBER, MD
- Assistant Clinical Professor
- Department of Family and Community Medicine
- University of Arkansas

He is a family physician in private practice in Jacksonville, Arkansas, and Assistant Clinical Professor, Department of Family and Community Medicine, University of Arkansas. He is a member of the Board of Directors of the American Academy of Family Physicians and served on the Surgery Technical Consulting Committee to the Harvard School of Public Health Resource-Based Relative Value Study on physician reimbursement.

- VON BEST WHITAKER, PhD, RN, C
- Assistant Professor
- School of Nursing
- University of Texas Health Science Center

She is an Assistant Professor in the School of Nursing at the University of Texas Health Science Center at San Antonio. She has a Master of Science in Community Health Nursing and a Master of Arts in Psychology. She is Chair of the American Society of Ophthalmic Registered Nurses Research Committee, a member of the American Public Health Association, and a member of a number of national organizations involved in ophthalmic nursing.

- IRA G. WONG, MD
- Chief, Department of Ophthalmology
- Kaiser Permanente Medical Center
- Assistant Clinical Professor
- University of California-San Francisco

He is a practicing ophthalmologist specializing in the medical and surgical treatment of diseases of the anterior segment of the eye. He is Chief of Ophthalmology for The Permanente Medical Group and the Kaiser Permanente Health Care Program in Northern California. He has served as a consultant to the Physicians Payment Review Commission and to the Health Care Financing Administration on a variety of cataract care issues.