# Glossary

Cataract: : An opacity of the crystalline lens of the eye; a loss of transparency of the lens of the eye or of its capsule.

Cataract surgery: : Removal of an opacified lens (cataract) from the eye to restore sight. See extracapsular cataract extraction surgery, intracapsular cataract surgery, phacoemulsification cataract surgery.

Complications:: Ailments secondary to the original complaint or the treatment; diseases or other disorders that arise in a patient from a preexisting disorder or from an unrelated cause within the same patient. Complications may result from treatment, e.g., postsurgical infection in a patient.

Contrast sensitivity tests:: Tests designed to measure the amount of contrast required to detect a specific stimulus. Contrast sensitivity testing attempts to determine the eye's ability to detect subtle variations of shading by presenting letters, figures, or sine wave gratings that are varied in contrast, luminance, and spatial frequency.

Cornea: : The transparent structure forming the anterior part of the fibrous tunic of the eye. It consists of five layers: the anterior corneal epithelium, continuous with that of the conjunctiva; the anterior limiting layer; the substantia propria; the posterior limiting layer; and the endothelium of the anterior chamber, called the keratoderma.

Cortical cataract: : A type of cataract in which there is progressive opacification of the outer shell of the lens.

Crystalline lens:: A transparent biconvex cellular body lying between the iris and the vitreous. One of the refracting media of the eye, it consists of a soft outer part (cortical substance) with a denser central part (nucleus). The lens is surrounded by a fine membrane, the capsule.

Extracapsular cataract extraction (ECCE) surgery: : Surgical removal of the cataractous lens from the lens capsule without concurrent removal of the lens capsule. In this procedure, the anterior capsule of the lens is removed, the nucleus of the cataract is expressed, and the residual cortical material is aspirated from the eye. The posterior capsule is left intact, and an intraocular lens is placed in the capsular bag, which restores vision.

Functional impairment: : When applied to cataracts, the degradation of a person's ability to function as he or she normally would if his or her vision were not impaired as a result of cataract.

Glare: : In persons with cataracts, the bright, blurred visual perception of light under certain conditions of bright light. Glare in persons with cataract is caused by lens opacities that scatter light.

Glare tests: : Tests that attempt to reproduce the symptom of glare in cataract patients and to quantify the amount of visual impairment it causes by comparing acuity with and without a bright light source directed by the eye. See glare.

Glaucoma:: A condition in which the pressure of the fluid in the eye becomes so great that it damages the small internal blood vessels and/or optic nerve fibers, resulting in nerve fiber destruction and partial or complete loss of vision. Glaucoma is one of the most common major eye disorders in people over 60.

Intracapsular cataract surgery: : A surgical technique for removing cataracts in which the whole lens in its capsule is extracted either by forceps or a cryoprobe to permit artificial lens implantation.

Intraocular lens (IOL):: An artificial lens that is implanted into the eyes of patients who have had their cataracts surgically removed and designed to restore the lost focusing power of the removed natural lens.

Lens capsule (capsule lentis): : The capsule enclosing the lens of the eye.

Lens opacity:: A lack of transparency in the lens.

Mixed opacities:: A combination of opacities involving different portions of the lens.

Nd:YAG capsulotomy: : The most commonly used technique for treating posterior capsular opacification, usually referred to as YAG capsulotomy. With this technique, an Nd:YAG laser is used to make a hole in the central part of the lens to improve vision. Nd and YAG are abbreviations that stand for neodymium and yttrium aluminum garnet. See posterior capsular opacification.

Nonsurgical management: : When applied to cataract patients, the use of nonsurgical techniques, such as education and counseling, to instruct patients on the effects and prognosis of their cataract condition. Also, the use of different prescription eyeglasses, magnifying lenses, visual aids, appropriate illumination, or pupillary dilation instead of surgery to enhance vision.

Nuclear sclerosis:: A type of cataract in which the central portion, or nucleus, gradually increases in density and opacification.

Phacoemulsification (PE) cataract surgery: : A surgical technique that is a modification of the extracapsular cataract extraction procedure whereby the nucleus of the cataract is fragmented by a probe oscillating at ultrasonic frequency and nuclear fragments are simultaneously aspirated from the eye. An intraocular lens is then implanted in the treated eye.

Posterior capsular opacification (PCO):: An opacification, or clouding, of the posterior lens capsule that may be a natural consequence of modern cataract surgery. The most common treatment for this condition is the Nd:YAG capsulotomy. See lens capsule, Nd:YAG capsulotomy, YAG capsulotomy.

Potential vision tests: : Subjective or objective tests designed to determine whether patients with obviously impaired vision have the potential to see well following cataract surgery. These tests attempt to ascertain whether the limiting factor to visual impairment is cataract rather than other pathology. Subjective tests include the superthreshold pinhole device, Maddox rod test, laser interferometer, and Guyton-Minkowski potential acuity meter. Electrophysiologic tests are objective tests in which the response to visual stimuli is measured electronically.

Preoperative medical tests: : Tests used to assist in determining the patient's medical suitability for surgery.

Preoperative ophthalmologic tests: : In cataract patients, various tests that have been used in an attempt to determine the effect of the cataract on visual function and assess the patient's visual needs in order to determine the most appropriate method of treatment or therapy. See contrast sensitivity tests, glare tests, potential vision tests, Snellen visual acuity test, specular photographic microscopy of the corneal endothelium.

Quality of life: : The attributes, nature, and condition of one's life. In health care, the term is often used to describe individuals' perception of the degree of value or meaningfulness associated with how they are able to conduct their lives, especially as that conduct is affected by their medical or health status.

Retina: : The innermost of the three tunics of the eyeball. It consists of three parts: pars optica-retinae, pars ciliaris, and pars iridica retinae.

Retinal detachment: : Separation of the inner layers of the retina (neural retina) from the pigment epithelium.

Risk factors: : Any acts, circumstances, or conditions that increase the probability of developing a disease or of experiencing an adverse effect.

Snellen visual acuity test: : A standard method of measuring visual acuity used during vision tests. Snellen's chart, bearing rows of letters of standard, decreasing size, is set at a predetermined distance from the patient. One eye is covered and the patient reads as far down the chart as possible. The procedure is repeated for the second eye.

Specular photographic microscopy of the corneal endothelium: : A research tool sometimes used to try to identify patients at risk for developing problems with their corneas as a result of cataract surgery. The test is used to examine and count a certain type of cell on the back surface of the cornea.

Visual acuity: : Sharpness (discrimination) of central vision, as opposed to peripheral vision. A person's visual acuity is measured during a vision test.

Visual function: : The sensory functioning of the eye; how well or poorly a person can see.

Visual impairment: : A decrease in visual function that is subjectively and/or objectively demonstrable. Any person may be considered visually impaired if the corrected distant visual acuity in the better eye is 20/80 or less or if visual fields are significantly restricted. See visual function.

YAG capsulotomy: : The usual term for the most commonly used technique for treating posterior capsular opacification. See Nd:YAG capsulotomy.